# SUMMARY AND DISCUSSION

## Key Findings and Strength of Evidence

- We found few randomized or controlled clinical trials or prospective clinical cohort studies comparing home-based and in-center kidney dialysis. Available clinical trials were small in size and had short follow-up durations.
- Most of the data on mortality is from registry studies. Results from these studies should be interpreted with caution due to likely residual confounding and selection bias.
- Home hemodialysis (HHD) versus in-center HD:
  - We found low strength of evidence (findings from registry studies) that HHD is associated with improved overall survival compared to in-center HD (Table 6). There were few studies of variations of HHD (including longer duration or more frequent sessions).
  - There is evidence from generally low-quality studies to suggest no difference in cardiovascular mortality, no difference or improved quality of life with HHD, no difference in access survival, no difference in transplantation rate, and no difference in all-cause hospitalization rate. In 2 studies reporting, a higher percentage of HHD patients switched dialysis modalities over follow-up periods of up to 4 years.
- Peritoneal dialysis (PD) versus in-center HD:
  - We found low strength of evidence (findings from registry studies) that there is no difference in overall mortality between PD to in-center HD (Table 6). However, most studies reporting outcomes over time noted an early survival advantage for PD patients with no difference after 2 to 3 years of treatment.
  - There were inconsistent findings for quality of life outcomes with studies reporting no differences or higher scores on some elements of quality of life in PD or in-center HD patients. With limited reporting, results were mixed for cardiovascular outcomes, adverse events, transplantation, and hospitalization. Over follow-up periods of 2 to 7 years, higher percentages of PD patients switched dialysis modalities.
- Only 2 studies compared HHD and PD with mixed results for mortality. Other outcomes were not reported.
- Factors associated with increased selection of home-based dialysis:
  ○ Facility factors: larger facility, more years of Medicare certification, providing care for more employed patients or patients in the 18 to 54 year age range, earlier initiation of pre-dialysis care, increased patient/family education;
  ○ Patient factors: well-informed about choices, patient preference (more autonomy, more flexible schedule, and less travel to dialysis), family/caregiver support;
  ○ Provider factors: team approach (physician, nurse, social worker) to determining patient eligibility (medical and psychosocial).
- Factors associated with decreased selection of home-based dialysis:
  ○ Facility factors: location in more rural area, location in high density zip code area, availability of an evening shift, higher percentage of black patients;
  ○ Patient factors: lack of knowledge, living alone, lack of space in the home, inability to perform PD in the place of residence, fear of social isolation, fear of inability to perform PD, and preference for medical supervision.
- Factors associated with technique failure:
  ○ Facility factors: lower technique failure if receiving care from larger dialysis facilities;
  ○ Patient factors: higher technique failure if lack of caregiver support, caregiver anxiety, medical issues (including diabetes or psychosocial problems), treatment interferes with home life, African-American race (vs white), HD before PD;
  ○ Provider factors: none identified.
- Costs are lower with HHD and PD compared to in-center HD but costs considered in the analyses and factors that can influence costs (failure rates, patient comorbidity) varied across studies.

Table 6 Strength of Evidence for Mortality Outcome

Outcome (studies reporting) | Results | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Overall Mortality HHD vs HD (6 registry studies) | 4 of 6 studies reported decreased overall mortality with HHD | high | consistent | direct | precise | low
Overall Mortality PD vs HD (19 registry studies) | 4 studies reported decreased mortality with PD 6 studies reported increased mortality with PD 9 studies reported no difference in mortality | high | inconsistent | direct | imprecise | low

HHD = home hemodialysis; HD = in-center hemodialysis; PD = peritoneal dialysis

This evidence report summarizes literature on the comparative effectiveness and harms of home-based versus in-center dialysis. Home-based dialysis is a potentially effective option of considerable interest to Veterans and could permit VA to expand internal dialysis capacity. However, it is not well known if this is feasible within the Veteran population, due to in part to a greater prevalence of patients of older age and a greater number of comorbidities in the VA system. None of the included studies were conducted at VA medical centers.

Data on clinical outcomes come predominately from large registry studies, not randomized controlled trials. While authors attempted to control for confounding, significant residual confounding from both measured and unmeasured variables likely exists. Patients who undergo home dialysis are generally different than those who undergo in-center dialysis. In the United States patients undergoing home dialysis are generally younger and healthier than those treated with in-center hemodialysis. Also, patients without insurance and those without pre-dialysis care who present emergently requiring dialysis are much more likely to be initiated on in-center hemodialysis. These differences in patient characteristics can be inferred by the greater rate of transplantation among patients undergoing peritoneal dialysis compared to those undergoing in-center hemodialysis, which may then result in artificially increased death rates in PD groups in later periods of follow-up. Given these stark differences between patient populations it is difficult to compare outcomes across these populations, irrespective of the type of statistical technique employed.

## DISCUSSION

Our findings are in agreement with earlier reviews and guidelines. A guideline from Caring for Australians with Renal Impairment (CARI) concluded that no clinical care recommendations could be made that would be based on Level I or Level II evidence.141 The authors offered clinical care suggestions based on Level III or Level IV evidence including that PD may provide equivalent or better survival in the first few years, the HD may offer better long-term survival, and that timely transfer from PD to HD may improve survival. Based on opinion, it was suggested that survival be considered in the context of life quality as perceived by the patient when selecting a dialysis modality.

Other reviews have identified health care system, provider, and patient factors that are important in selection of home-based dialysis. Golper et al summarized barriers to home dialysis as educational issues (patient education; physician education, training, and experience; and dialysis staff education and experiences), governmental issues (reimbursement, financial support for home caregivers, accreditation and certification, required home visits, and regulatory policies that limit access to innovative equipment and solutions), and business practices and philosophies of dialysis providers (availability and delivery of equipment and supplies, business conflicts with patient care, laboratory and pharmacy services availability, space for training and clinic visits, and staffing).142

A second review focused on establishing a successful HHD program.143 Patient education (including training on and practice with the equipment), physician training, nurse training (to prepare them to train patients), and staff support for patients and caregivers are essential. The creation of centralized training facilities (combining resources from multiple practices) and the use of continuous quality improvement cycles to monitor and modify treatment protocols were also suggested. The authors provided information on best demonstrated practices related to choice of dialysis equipment, dialysis schedule, vascular access, and remote monitoring; design of the patient training program; home assessment; post-training expectations; and patient or family burnout.

In a 2006 publication, patient preference (in the absence of a strong indications for or against a particular modality), medical factors, social issues, and non-medical issues (including financial reimbursement, late referral to a nephrologist, and nephrologist attitudes, opinions, educational deficits, and biases) were described as contributing factors in selection of a dialysis modality.144 The authors proposed an integrated care approach with early referral, aggressive management of CKD, promotion of living donor transplantation as first-line treatment for ESRD, unbiased education about all dialysis modalities, encouragement for suitable patients to select a home-based modality as initial therapy, and recognition that treatment modalities may be complementary rather than competing in providing optimal outcomes.

A 2013 meta-analysis focused on the modality decision-making process.145 The analysis included 16 qualitative studies of adults (total n=410) with CKD. All but one of the studies was conducted in North America, Europe, or Australia/New Zealand. Across the studies, 3 themes emerged. First, patients perceived they had little true choice about commencing dialysis or dialysis modality – dialysis was necessary for survival. Often the choice was made in a short time frame by family or physician due to unforeseen medical situations. Second, minimizing intrusiveness was important. Patients believed that dialysis should allow for a good quality of life in addition to prolonging life. Third, knowledge (for both the patient and family members) and social support were important. The authors concluded that there is a need for CKD patients and their caregivers to participate in planned and timely discussions about dialysis modalities, including home-based care. Healthcare professionals should prepare patients and families for decision-making and provide information about different dialysis modalities and potential effects on quality of life, values, autonomy, and sense of self.

Overall treatment satisfaction with PD was the focus of another 2013 systematic review.146 Included were 39 qualitative studies of the experiences, beliefs, and attitudes about PD from adults on long-term PD. Sample sizes in the individual studies ranged from 2 to 45 with 4 studies not reporting sample size. All but 4 studies were from North America, Europe, or Australia/New Zealand. Seven major themes were identified and these were subsequently organized into a thematic schema. “Resilience and confidence” (determination, overcoming anxieties associated with diagnosis of ESRD) and positive “support structure” (strong family relationship, peer support, professional dedication) contributed to a positive adjustment to PD. A positive adjustment resulted in perceptions of “control” (bodily awareness, independence and self-efficacy, information seeking) and “freedom” (treatment integration, social functioning, ability to travel). “Overwhelming responsibility” (disruptive intrusion, family burden, onerous treatment regimen) and negative “support structure” (social abandonment, desire for holistic care) contributed to a negative adjustment to PD which resulted in perceptions of a “sick identity” (damage to self-esteem, invisible suffering) and “disablement” (physical incapacitation, social loss and devaluation). It was concluded that while PD can have advantages for patients, strategies to strengthen social support and promote confidence are necessary for achieving positive adjustment and treatment satisfaction.

There is limited data on caregiver burden associated with dialysis and whether HHD is more stressful for caregivers. In a study from Italy, where HHD is rare, patients and caregivers were interviewed.147 The 22 adult patients were currently receiving in-center HD; some were potentially eligible for HHD. The 20 caregivers, identified by the patients, were adults who provided care or support on a regular basis. The participants were selected to represent both genders and a range of ages, durations of dialysis, years of caregiving, and relationships to patients. Positive and negative themes were identified. On the positive side, flexibility and freedom, comfort in familiar surroundings, and altruistic motivation (setting an example for others) emerged. Negative themes included disrupted sense of normality, family burden, housing constraints, concern over healthcare by “amateurs,” and isolation from peer support. Specifically, both patients and caregivers thought that HHD would be an “overwhelming responsibility” for a caregiver. Caregiving would require “significant personal sacrifices” that would impact work and social lives. Caregivers were concerned about seeing the patient “suffer” while undergoing dialysis, their ability to assist the patient with treatment and technical problems or complications that might arise, and their ability to manage “medical responsibilities.” Caregivers also reported that they perceived patients were content with their in-center care and that they benefited from peer support. The authors identified education, providing support for caregivers and family members, minimizing the intrusiveness of HHD, maintaining patient access to medical and technical support, minimizing social isolation, and promoting self-efficacy as ways to increase acceptability and selection of HHD. Suri et al reported results from the Frequent Hemodialysis Network Trials.148 Patients in the Daily Trial completed dialysis in-center either 3 or 6 times per week while those in the Nocturnal Trial completed dialysis at home with either conventional dialysis 3 times per week or nocturnal dialysis 6 times per week. The analysis included patients who reported having an unpaid caregiver. Scores on a perceived burden scale at 4 and 12 months were lower than baseline (indicating less perceived caregiver burden) for the Daily Trial participants regardless of dialysis schedule and for the conventional home dialysis patients. Scores increased from baseline (indicating greater perceived caregiver burden) at 4 and 12 months for the nocturnal home dialysis patients. The authors suggested that the findings may play a role in the choice of frequent home nocturnal dialysis.

## LIMITATIONS

Two studies found no difference in transplantation rates between HHD and HD. This finding may be a result of the length of time before a donor kidney becomes available. Studies with short follow-up could demonstrate no difference.

If there is an advantage of HHD over HD, it may be related to the different frequencies of dialysis or treatment times per session that are possible with HHD.22

Quality of life outcomes should be interpreted with caution. Often the studies are comparing groups of patients with different amounts of time on dialysis (eg, quality of life assessed at 3 months in one group versus 15 months in the other group). Familiarity with and adjustment to dialysis and/or disease progression might be more important factors in reported quality of life than the dialysis modality. In addition, baseline characteristics (eg, age, comorbidities) of the patients in the treatment groups differ and might account for differences in reported quality of life. Finally, assessment of quality of life during an in-center HD session versus at home or during a routine office visit (no dialysis) may yield different quality of life scores. The use of generic versus disease specific assessment tools should also be considered.

### Applicability of Findings to the VA Population

Twenty of the 32 registry studies were completed in the United States or Canada. Across all registry studies, mean ages ranged from 47 to 75 years and between 50% and 67% of included patients were male. There were few exclusion criteria, suggesting that the patients were representative of the ESRD population. However, the cohort years for all but 7 of the registry studies were prior to 2008.

We found no compelling evidence that HHD and PD differ from in-center HD in survival, quality of life, hospitalizations, or costs. Differences, where they exist, could be due to unmeasured differences in patient populations and strong selection biases (by patients, caregivers, or providers). However, HHD and PD are commonly used as the dialysis method of choice in other countries. We also found some evidence that caregiver support was an important factor in identifying candidates likely suitable for HHD or PD.

## RESEARCH GAPS/FUTURE RESEARCH

Despite the large number of studies included in this report considerable gaps exist. The comparative effectiveness of HHD or PD to in-center HD (including outcomes of mortality, hospitalizations, quality of life, patient satisfaction, and adverse events) and whether treatment choice and technique success vary by modality, patient, provider, or facility factors remains relatively unknown. This is predominately because considerable differences likely exist among individuals selected (or selecting) different treatment modalities. While difficult to undertake, a large randomized trial comparing different modalities would be useful. Other research needs would be to evaluate methods to understand barriers to and improve implementation of HHD or PD and provide individuals with sufficient skill building and caregiver support in attempts to maximize benefits. Of note HHD and PD are widely used as treatment options of choice in other developed countries.

## CONCLUSIONS

Low-strength evidence suggests that home-based dialysis may provide similar health outcomes and at similar or lower costs for many patients compared to in-center hemodialysis. Therefore, home-based dialysis may be an acceptable and sometimes preferred alternative to in-center hemodialysis. Information is limited on factors important in addressing selection of and barriers to home-based dialysis and remains an area of important research and health policy.