# REFERENCES

1 Piccoli GB, Ferraresi M, Consiglio V, et al. Why home hemodialysis? A systematic “marketing” analysis. J Nephrol. Mar-Apr. 2012;25(2):159-169. [pmid: 22322823].
2 Mowatt G, Vale L, MacLeod A. Systematic review of the effectiveness of home versus hospital or satellite unit hemodialysis for people with end-stage renal failure. Int J Technol Assess Health Care. 2004;20(3):258-268. [pmid: 15446754].
3 US Renal Data System. 2014 Annual Data Report: An Overview of the Epidemiology of Kidney Disease in the United States. Bethesda, MD. National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. 2014.
4 Higgins H, Green S. Cochrane Handbook for Systeamtic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. 2011. http://handbook.cochrane.org. August 31, 2014.
5 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
6 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC medical research methodology. 2007;7:10. [pmid: 17302989].
7 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of clinical epidemiology. May. 2010;63(5):513-523. [pmid: 19595577].
8 Weinhandl ED, Liu J, Gilbertson DT, Arneson TJ, Collins AJ. Survival in daily home hemodialysis and matched thrice-weekly in-center hemodialysis patients. J Am Soc Nephrol. May. 2012;23(5):895-904. [pmid: 22362906].
9 MacRae JM, Rose CL, Jaber BL, Gill JS. Utilization and outcome of ‘out-of-center hemodialysis’ in the United States: a contemporary analysis. Nephron. 2010;116(1):c53-59. [pmid: 20502039].
10 Woods JD, Port FK, Stannard D, Blagg CR, Held PJ. Comparison of mortality with home hemodialysis and center hemodialysis: a national study. Kidney Int. May. 1996;49(5):1464-1470. [pmid: 8731115].
11 Marshall MR, Walker RC, Polkinghorne KR, Lynn KL. Survival on home dialysis in New Zealand. PloS one. 2014;9(5):e96847. [pmid: 24806458].
12 Marshall MR, Hawley CM, Kerr PG, et al. Home hemodialysis and mortality risk in Australian and New Zealand populations. Am J Kidney Dis. Nov. 2011;58(5):782-793. [pmid: 21816526].
13 Nesrallah GE, Lindsay RM, Cuerden MS, et al. Intensive hemodialysis associates with improved survival compared with conventional hemodialysis. J Am Soc Nephrol. Apr. 2012;23(4):696-705. [pmid: 22362910].
14 Nitsch D, Steenkamp R, Tomson CRV, Roderick P, Ansell D, MacGregor MS. Outcomes in patients on home haemodialysis in England and Wales, 1997-2005: a comparative cohort analysis. Nephrol Dial Transplant. May. 2011;26(5):1670-1677. [pmid: 20841489].
15 Culleton BF, Walsh M, Klarenbach SW, et al. Effect of frequent nocturnal hemodialysis vs conventional hemodialysis on left ventricular mass and quality of life: a randomized controlled trial. Jama. Sep. 19. 2007;298(11):1291-1299. [pmid: 17878421].
16 McGregor DO, Buttimore AL, Lynn KL, Nicholls MG, Jardine DL. A Comparative Study of Blood Pressure Control with Short In-Center versus Long Home Hemodialysis. Blood purification. 2001;19(3):293-300. [pmid: 11244189].
17 Xue H, Li NC, Lacson E Jr., Brunelli SM, Lockridge RS. Catheter-related bacteremia and mortality in frequent nocturnal home hemodialysis. Hemodialysis international. International Symposium on Home Hemodialysis. Apr. 2015;19(2):242-248. [pmid: 25645402].
18 Kjellstrand CM, Buoncristiani U, Ting G, et al. Short daily haemodialysis: survival in 415 patients treated for 1006 patient-years. Nephrol Dial Transplant. Oct. 2008;23(10):3283-3289. [pmid: 18458034].
19 Lindsay RM, Leitch R, Heidenheim AP, Kortas C, London Daily/Nocturnal Hemodialysis S. The London Daily/Nocturnal Hemodialysis Study--study design, morbidity, and mortality results. Am J Kidney Dis. Jul. 2003;42(1 Suppl):5-12. [pmid: 12830437].
20 Weinhandl ED, Nieman KM, Gilbertson DT, Collins AJ. Hospitalization in daily home hemodialysis and matched thrice-weekly in-center hemodialysis patients. Am J Kidney Dis. Jan. 2015;65(1):98-108. [pmid: 25085647].
21 Heidenheim AP, Muirhead N, Moist L, Lindsay RM. Patient quality of life on quotidian hemodialysis. Am J Kidney Dis. Jul. 2003;42(1 Suppl):36-41. [pmid: 12830442].
22 Griva K, Davenport A, Harrison M, Newman S. An evaluation of illness, treatment perceptions, and depression in hospital- vs. home-based dialysis modalities. Journal of psychosomatic research. Oct. 2010;69(4):363-370. [pmid: 20846537].
23 Wight JP, Edwards L, Brazier J, Walters S, Payne JN, Brown CB. The SF36 as an outcome measure of services for end stage renal failure. Quality in health care : QHC. Dec. 1998;7(4):209-221. [pmid: 10339023].
24 Molzahn AE, Northcott HC, Dossetor JB. Quality of life of individuals with end stage renal disease: perceptions of patients, nurses, and physicians. ANNA journal / American Nephrology Nurses' Association. Jun. 1997;24(3):325-333. discussion 334-325. [pmid: 9238904].
25 Quintaliani G, Buoncristiani U, Fagugli R, et al. Survival of vascular access during daily and three times a week hemodialysis. Clinical nephrology. May. 2000;53(5):372-377. [pmid: 11305810].
26 Lukowsky LR, Mehrotra R, Kheifets L, Arah OA, Nissenson AR, Kalantar-Zadeh K. Comparing mortality of peritoneal and hemodialysis patients in the first 2 years of dialysis therapy: a marginal structural model analysis. Clin J Am Soc Nephrol. Apr. 2013;8(4):619-628. [pmid: 23307879].
27 Lievense H, Kalantar-Zadeh K, Lukowsky LR, et al. Relationship of body size and initial dialysis modality on subsequent transplantation, mortality and weight gain of ESRD patients. Nephrol Dial Transplant. Sep. 2012;27(9):3631-3638. [pmid: 22553372].
28 Mehrotra R, Chiu YW, Kalantar-Zadeh K, Bargman J, Vonesh E. Similar outcomes with hemodialysis and peritoneal dialysis in patients with end-stage renal disease. Arch Intern Med. Jan. 24. 2011;171(2):110-118. [pmid: 20876398].
29 Weinhandl ED, Foley RN, Gilbertson DT, Arneson TJ, Snyder JJ, Collins AJ. Propensity-matched mortality comparison of incident hemodialysis and peritoneal dialysis patients. J Am Soc Nephrol. Mar. 2010;21(3):499-506. [pmid: 20133483].
30 Collins AJ, Weinhandl E, Snyder JJ, Chen SC, Gilbertson D. Comparison and survival of hemodialysis and peritoneal dialysis in the elderly. Seminars in dialysis. Mar-Apr. 2002;15(2):98-102. [pmid: 11952935].
31 Abbott KC, Glanton CW, Trespalacios FC, et al. Body mass index, dialysis modality, and survival: analysis of the United States Renal Data System Dialysis Morbidity and Mortality Wave II Study. Kidney Int. Feb. 2004;65(2):597-605. [pmid: 14717930].
32 Vonesh EF, Snyder JJ, Foley RN, Collins AJ. The differential impact of risk factors on mortality in hemodialysis and peritoneal dialysis. Kidney Int. Dec. 2004;66(6):2389-2401. [pmid: 15569331].
33 Stack AG, Molony DA, Rahman NS, Dosekun A, Murthy B. Impact of dialysis modality on survival of new ESRD patients with congestive heart failure in the United States. Kidney Int. Sep. 2003;64(3):1071-1079. [pmid: 12911559].
34 Xue JL, Everson SE, Constantini EG, et al. Peritoneal and hemodialysis: II. Mortality risk associated with initial patient characteristics. Kidney Int. Feb. 2002;61(2):741-746. [pmid: 11849418].
35 Collins AJ, Hao W, Xia H, et al. Mortality risks of peritoneal dialysis and hemodialysis. Am J Kidney Dis. Dec. 1999;34(6):1065-1074. [pmid: 10585316].
36 Bloembergen WE, Port FK, Mauger EA, Wolfe RA. A comparison of mortality between patients treated with hemodialysis and peritoneal dialysis. J Am Soc Nephrol. Aug. 1995;6(2):177-183. [pmid: 7579082].
37 Lowrie EG, Huang WH, Lew NL. Death risk predictors among peritoneal dialysis and hemodialysis patients: a preliminary comparison. Am J Kidney Dis. Jul. 1995;26(1):220-228. [pmid: 7611256].
38 McDonald SP, Marshall MR, Johnson DW, Polkinghorne KR. Relationship between dialysis modality and mortality. J Am Soc Nephrol. Jan. 2009;20(1):155-163. [pmid: 19092128].
39 Yeates K, Zhu N, Vonesh E, Trpeski L, Blake P, Fenton S. Hemodialysis and peritoneal dialysis are associated with similar outcomes for end-stage renal disease treatment in Canada. Nephrol Dial Transplant. Sep. 2012;27(9):3568-3575. [pmid: 22391139].
40 Schaubel DE, Morrison HI, Fenton SS. Comparing mortality rates on CAPD/CCPD and hemodialysis. The Canadian experience: fact or fiction?. Perit Dial Int. Sep-Oct. 1998;18(5):478-484. [pmid: 9848625].
41 Fenton SS, Schaubel DE, Desmeules M, et al. Hemodialysis versus peritoneal dialysis: a comparison of adjusted mortality rates. Am J Kidney Dis. Sep. 1997;30(3):334-342. [pmid: 9292560].
42 Quinn RR, Hux JE, Oliver MJ, Austin PC, Tonelli M, Laupacis A. Selection bias explains apparent differential mortality between dialysis modalities. J Am Soc Nephrol. Aug. 2011;22(8):1534-1542. [pmid: 21784891].
43 Liem YS, Wong JB, Hunink MGM, de Charro FT, Winkelmayer WC. Comparison of hemodialysis and peritoneal dialysis survival in The Netherlands. Kidney Int. Jan. 2007;71(2):153-158. [pmid: 17136031].
44 van de Luijtgaarden MWM, Noordzij M, Stel VS, et al. Effects of comorbid and demographic factors on dialysis modality choice and related patient survival in Europe. Nephrol Dial Transplant. Sep. 2011;26(9):2940-2947. [pmid: 21325351].
45 Haapio M, Helve J, Kyllonen L, Gronhagen-Riska C, Finne P. Modality of chronic renal replacement therapy and survival--a complete cohort from Finland, 2000-2009. Nephrol Dial Transplant. Dec. 2013;28(12):3072-3081. [pmid: 24030833].
46 Sens F, Schott-Pethelaz AM, Labeeuw M, Colin C, Villar E, Registry R. Survival advantage of hemodialysis relative to peritoneal dialysis in patients with end-stage renal disease and congestive heart failure. Kidney Int. Nov. 2011;80(9):970-977. [pmid: 21775972].
47 Locatelli F, Marcelli D, Conte F, et al. Survival and development of cardiovascular disease by modality of treatment in patients with end-stage renal disease. J Am Soc Nephrol. Nov. 2001;12(11):2411-2417. [pmid: 11675417].
48 Mircescu G, Stefan G, Garneata L, Mititiuc I, Siriopol D, Covic A. Outcomes of dialytic modalities in a large incident registry cohort from Eastern Europe: the Romanian Renal Registry. Int Urol Nephrol. Feb. 2014;46(2):443-451. [pmid: 24162889].
49 Traynor JP, Thomson PC, Simpson K, et al. Comparison of patient survival in non-diabetic transplant-listed patients initially treated with haemodialysis or peritoneal dialysis. Nephrol Dial Transplant. Jan. 2011;26(1):245-252. [pmid: 20659905].
50 Korevaar JC, Feith GW, Dekker FW, et al. Effect of starting with hemodialysis compared with peritoneal dialysis in patients new on dialysis treatment: a randomized controlled trial. Kidney Int. Dec. 2003;64(6):2222-2228. [pmid: 14633146].
51 Jaar BG, Coresh J, Plantinga LC, et al. Comparing the risk for death with peritoneal dialysis and hemodialysis in a national cohort of patients with chronic kidney disease. [Summary for patients in Ann Intern Med. 2005 Aug 2;143(3):I17; PMID: 16061913]. Ann Intern Med. Aug. 2. 2005;143(3):174-183. [pmid: 16061915].
52 Noordzij M, Korevaar JC, Bos WJ, et al. Mineral metabolism and cardiovascular morbidity and mortality risk: peritoneal dialysis patients compared with haemodialysis patients. Nephrol Dial Transplant. Sep. 2006;21(9):2513-2520. [pmid: 16799173].
53 Termorshuizen F, Korevaar JC, Dekker FW, et al. Hemodialysis and peritoneal dialysis: comparison of adjusted mortality rates according to the duration of dialysis: analysis of The Netherlands Cooperative Study on the Adequacy of Dialysis 2. J Am Soc Nephrol. Nov. 2003;14(11):2851-2860. [pmid: 14569095].
54 Stack AG, Murthy BVR, Molony DA. Survival differences between peritoneal dialysis and hemodialysis among “large” ESRD patients in the United States. Kidney Int. Jun. 2004;65(6):2398-2408. [pmid: 15149353].
55 Ganesh SK, Hulbert-Shearon T, Port FK, Eagle K, Stack AG. Mortality differences by dialysis modality among incident ESRD patients with and without coronary artery disease. J Am Soc Nephrol. Feb. 2003;14(2):415-424. [pmid: 12538742].
56 Aslam N, Bernardini J, Fried L, Burr R, Piraino B. Comparison of infectious complications between incident hemodialysis and peritoneal dialysis patients. Clin J Am Soc Nephrol. Nov. 2006;1(6):1226-1233. [pmid: 17699352].
57 Mittal SK, Ahern L, Flaster E, Mittal VS, Maesaka JK, Fishbane S. Self-assessed quality of life in peritoneal dialysis patients. Am J Nephrol. May-Jun. 2001;21(3):215-220. [pmid: 11423691].
58 Harris SA, Lamping DL, Brown EA, Constantinovici N, North Thames Dialysis Study G. Clinical outcomes and quality of life in elderly patients on peritoneal dialysis versus hemodialysis. Perit Dial Int. Jul-Aug. 2002;22(4):463-470. [pmid: 12322817].
59 Boateng EA, East L. The impact of dialysis modality on quality of life: a systematic review. Journal of renal care. Dec. 2011;37(4):190-200. [pmid: 22035363].
60 Kutner NG, Zhang R, McClellan WM. Patient-reported quality of life early in dialysis treatment: effects associated with usual exercise activity. Nephrology nursing journal : journal of the American Nephrology Nurses' Association. Aug. 2000;27(4):357-367. discussion 368, 424. [pmid: 11276627].
61 Diaz-Buxo JA, Lowrie EG, Lew NL, Zhang H, Lazarus JM. Quality-of-life evaluation using Short Form 36: comparison in hemodialysis and peritoneal dialysis patients. Am J Kidney Dis. Feb. 2000;35(2):293-300. [pmid: 10676729].
62 Wu AW, Fink NE, Marsh-Manzi JVR, et al. Changes in quality of life during hemodialysis and peritoneal dialysis treatment: generic and disease specific measures. J Am Soc Nephrol. Mar. 2004;15(3):743-753. [pmid: 14978177].
63 Plantinga LC, Fink NE, Harrington-Levey R, et al. Association of social support with outcomes in incident dialysis patients. Clin J Am Soc Nephrol. Aug. 2010;5(8):1480-1488. [pmid: 20430940].
64 Jansen DL, Heijmans MJWM, Rijken M, et al. Illness perceptions and treatment perceptions of patients with chronic kidney disease: different phases, different perceptions?. Br J Health Psychol. May. 2013;18(2):244-262. [pmid: 23126527].
65 Thong MS, Kaptein AA, Krediet RT, Boeschoten EW, Dekker FW. Social support predicts survival in dialysis patients. Nephrol Dial Transplant. Mar. 2007;22(3):845-850. [pmid: 17164318].
66 Merkus MP, Jager KJ, Dekker FW, De Haan RJ, Boeschoten EW, Krediet RT. Quality of life over time in dialysis: the Netherlands Cooperative Study on the Adequacy of Dialysis. NECOSAD Study Group. Kidney Int. Aug. 1999;56(2):720-728. [pmid: 10432414].
67 Lee AJ, Morgan CL, Conway P, Currie CJ. Characterisation and comparison of health-related quality of life for patients with renal failure. Current medical research and opinion. Nov. 2005;21(11):1777-1783. [pmid: 16307698].
68 Kalirao P, Pederson S, Foley RN, et al. Cognitive impairment in peritoneal dialysis patients. Am J Kidney Dis. Apr. 2011;57(4):612-620. [pmid: 21295896].
69 Wyld M, Morton RL, Hayen A, Howard K, Webster AC. A systematic review and meta-analysis of utility-based quality of life in chronic kidney disease treatments. PLoS medicine. 2012;9(9):e1001307. [pmid: 22984353].
70 Purnell TS, Auguste P, Crews DC, et al. Comparison of life participation activities among adults treated by hemodialysis, peritoneal dialysis, and kidney transplantation: a systematic review. Am J Kidney Dis. Nov. 2013;62(5):953-973. [pmid: 23725972].
71 van Diepen AT, Hoekstra T, Rotmans JI, et al. The association between dialysis modality and the risk for dialysis technique and non-dialysis technique-related infections. Nephrol Dial Transplant. Dec. 2014;29(12):2244-2250. [pmid: 25170096].
72 Oliver MJ, Verrelli M, Zacharias JM, et al. Choosing peritoneal dialysis reduces the risk of invasive access interventions. Nephrol Dial Transplant. Feb. 2012;27(2):810-816. [pmid: 21693682].
73 Bruno MJ, van Westerloo DJ, van Dorp WT, et al. Acute pancreatitis in peritoneal dialysis and haemodialysis: risk, clinical course, outcome, and possible aetiology. Gut. Mar. 2000;46(3):385-389. [pmid: 10673301].
74 Van Biesen W, Vanholder RC, Veys N, Dhondt A, Lameire NH. An evaluation of an integrative care approach for end-stage renal disease patients. J Am Soc Nephrol. Jan. 2000;11(1):116-125. [pmid: 10616847].
75 Cano AE, Neil AK, Kang JY, et al. Gastrointestinal symptoms in patients with end-stage renal disease undergoing treatment by hemodialysis or peritoneal dialysis. Am J Gastroenterol. Sep. 2007;102(9):1990-1997. [pmid: 17511755].
76 Portoles J, Del Peso G, Fernandez-Reyes MJ, Bajo MA, Lopez-Sanchez P, Gcdp. Previous comorbidity and lack of patient free choice of technique predict early mortality in peritoneal dialysis. Perit Dial Int. Mar-Apr. 2009;29(2):150-157. [pmid: 19293351].
77 Liberek T, Renke M, Skonieczny B, et al. Therapy outcome in peritoneal dialysis patients transferred from haemodialysis. Nephrol Dial Transplant. Sep. 2009;24(9):2889-2894. [pmid: 19342418].
78 Mujais S, Story K. Peritoneal dialysis in the US: evaluation of outcomes in contemporary cohorts. Kidney Int Suppl. Nov. 2006;(103):S21-26. [pmid: 17080107].
79 Walker DR, Inglese GW, Sloand JA, Just PM. Dialysis facility and patient characteristics associated with utilization of home dialysis. Clin J Am Soc Nephrol. Sep. 2010;5(9):1649-1654. [pmid: 20634324].
80 Pipkin M, Eggers PW, Larive B, et al. Recruitment and training for home hemodialysis: experience and lessons from the Nocturnal Dialysis Trial. Clin J Am Soc Nephrol. Sep. 2010;5(9):1614-1620. [pmid: 20576829].
81 Morton RL, Howard K, Webster AC, Snelling P. Patient INformation about Options for Treatment (PINOT): a prospective national study of information given to incident CKD Stage 5 patients. Nephrol Dial Transplant. Apr. 2011;26(4):1266-1274. [pmid: 20819955].
82 Oliver MJ, Garg AX, Blake PG, et al. Impact of contraindications, barriers to self-care and support on incident peritoneal dialysis utilization. Nephrol Dial Transplant. Aug. 2010;25(8):2737-2744. [pmid: 20189930].
83 Oliver MJ, Quinn RR, Richardson EP, Kiss AJ, Lamping DL, Manns BJ. Home care assistance and the utilization of peritoneal dialysis. Kidney Int. Apr. 2007;71(7):673-678. [pmid: 17264874].
84 Jager KJ, Korevaar JC, Dekker FW, Krediet RT, Boeschoten EW, Netherlands Cooperative Study on the Adequacy of Dialysis Study G. The effect of contraindications and patient preference on dialysis modality selection in ESRD patients in The Netherlands. Am J Kidney Dis. May. 2004;43(5):891-899. [pmid: 15112180].
85 Thamer M, Hwang W, Fink NE, et al. US nephrologists' recommendation of dialysis modality: results of a national survey. Am J Kidney Dis. Dec. 2000;36(6):1155-1165. [pmid: 11096040].
86 Prichard SS. Treatment modality selection in 150 consecutive patients starting ESRD therapy. Perit Dial Int. Jan-Feb. 1996;16(1):69-72. [pmid: 8616177].
87 Jayanti A, Morris J, Stenvinkel P, Mitra S. Home hemodialysis: beliefs, attitudes, and practice patterns. Hemodialysis international. International Symposium on Home Hemodialysis. Oct. 2014;18(4):767-776. [pmid: 24814711].
88 Tennankore KK, Hingwala J, Watson D, Bargman JM, Chan CT. Attitudes and perceptions of nephrology nurses towards dialysis modality selection: a survey study. BMC Nephrol. 2013;14:192. [pmid: 24020978].
89 Manns BJ, Taub K, Vanderstraeten C, et al. The impact of education on chronic kidney disease patients' plans to initiate dialysis with self-care dialysis: a randomized trial. Kidney Int. Oct. 2005;68(4):1777-1783. [pmid: 16164654].
90 McLaughlin K, Jones H, VanderStraeten C, et al. Why do patients choose self-care dialysis?. Nephrol Dial Transplant. Dec. 2008;23(12):3972-3976. [pmid: 18577531].
91 McLaughlin K, Manns B, Mortis G, Hons R, Taub K. Why patients with ESRD do not select self-care dialysis as a treatment option. Am J Kidney Dis. Feb. 2003;41(2):380-385. [pmid: 12552500].
92 Ribitsch W, Haditsch B, Otto R, et al. Effects of a pre-dialysis patient education program on the relative frequencies of dialysis modalities. Perit Dial Int. Jul-Aug. 2013;33(4):367-371. [pmid: 23547278].
93 Lacson E Jr., Wang W, DeVries C, et al. Effects of a nationwide predialysis educational program on modality choice, vascular access, and patient outcomes. Am J Kidney Dis. Aug. 2011;58(2):235-242. [pmid: 21664016].
94 Rubin HR, Fink NE, Plantinga LC, Sadler JH, Kliger AS, Powe NR. Patient ratings of dialysis care with peritoneal dialysis vs hemodialysis. Jama. Feb. 11. 2004;291(6):697-703. [pmid: 14871912].
95 Keating PT, Walsh M, Ribic CM, Brimble KS. The impact of patient preference on dialysis modality and hemodialysis vascular access. BMC Nephrol. 2014;15:38. [pmid: 24558955].
96 Maaroufi A, Fafin C, Mougel S, et al. Patients' preferences regarding choice of end-stage renal disease treatment options. Am J Nephrol. 2013;37(4):359-369. [pmid: 23548342].
97 Chanouzas D, Ng KP, Fallouh B, Baharani J. What influences patient choice of treatment modality at the pre-dialysis stage?. Nephrol Dial Transplant. Apr. 2012;27(4):1542-1547. [pmid: 21865216].
98 Ravani P, Marinangeli G, Stacchiotti L, Malberti F. Structured pre-dialysis programs: more than just timely referral?. Jn, J. Nov-Dec. 2003;16(6):862-869.
99 Gadallah MF, Ramdeen G, Torres-Rivera C, et al. Changing the trend: a prospective study on factors contributing to the growth rate of peritoneal dialysis programs. Adv Perit Dial. 2001;17:122-126. [pmid: 11510258].
100 Bass EB, Wills S, Fink NE, et al. How strong are patients' preferences in choices between dialysis modalities and doses?. Am J Kidney Dis. Oct. 2004;44(4):695-705. [pmid: 15384021].
101 Winkelmayer WC, Glynn RJ, Levin R, Owen W Jr., Avorn J. Late referral and modality choice in end-stage renal disease. Kidney Int. Oct. 2001;60(4):1547-1554. [pmid: 11576371].
102 Barker-Cummings C, McClellan W, Soucie JM, Krisher J. Ethnic differences in the use of peritoneal dialysis as initial treatment for end-stage renal disease. Jama. Dec. 20. 1995;274(23):1858-1862. [pmid: 7500535].
103 Shen JI, Mitani AA, Saxena AB, Goldstein BA, Winkelmayer WC. Determinants of peritoneal dialysis technique failure in incident US patients. Perit Dial Int. Mar-Apr. 2013;33(2):155-166. [pmid: 23032086].
104 Lobbedez T, Verger C, Ryckelynck JP, Fabre E, Evans D. Is assisted peritoneal dialysis associated with technique survival when competing events are considered?. Clin J Am Soc Nephrol. Apr. 2012;7(4):612-618. [pmid: 22344506].
105 Smyth A, McCann E, Redahan L, Lambert B, Mellotte GJ, Wall CA. Peritoneal dialysis in an ageing population: a 10-year experience. Int Urol Nephrol. Feb. 2012;44(1):283-293. [pmid: 21537856].
106 Taveras AE, Bekui AM, Gorban-Brennan N, Raducu R, Finkelstein FO. Peritoneal dialysis in patients 75 years of age and older--a 22-year experience. Adv Perit Dial. 2012;28:84-88. [pmid: 23311220].
107 Kolesnyk I, Dekker FW, Boeschoten EW, Krediet RT. Time-dependent reasons for peritoneal dialysis technique failure and mortality. Perit Dial Int. Mar-Apr. 2010;30(2):170-177. [pmid: 20124193].
108 Singh N, Davidson I, Minhajuddin A, Gieser S, Nurenberg M, Saxena R. Risk factors associated with peritoneal dialysis catheter survival: a 9-year single-center study in 315 patients. J. Oct-Dec. 2010;11(4):316-322.
109 Jaar BG, Plantinga LC, Crews DC, et al. Timing, causes, predictors and prognosis of switching from peritoneal dialysis to hemodialysis: a prospective study. BMC Nephrol. 2009;10:3. [pmid: 19200383].
110 Plantinga LC, Fink NE, Finkelstein FO, Powe NR, Jaar BG. Association of peritoneal dialysis clinic size with clinical outcomes. Perit Dial Int. May-Jun. 2009;29(3):285-291. [pmid: 19458300].
111 Tonelli M, Hemmelgarn B, Culleton B, et al. Mortality of Canadians treated by peritoneal dialysis in remote locations. Kidney Int. Oct. 2007;72(8):1023-1028. [pmid: 17637709].
112 McDonald SP, Collins JF, Johnson DW. Obesity is associated with worse peritoneal dialysis outcomes in the Australia and New Zealand patient populations. J Am Soc Nephrol. Nov. 2003;14(11):2894-2901. [pmid: 14569099].
113 Snyder JJ, Foley RN, Gilbertson DT, Vonesh EF, Collins AJ. Body size and outcomes on peritoneal dialysis in the United States. Kidney Int. Nov. 2003;64(5):1838-1844. [pmid: 14531819].
114 Jager KJ, Merkus MP, Dekker FW, et al. Mortality and technique failure in patients starting chronic peritoneal dialysis: results of The Netherlands Cooperative Study on the Adequacy of Dialysis. NECOSAD Study Group. Kidney Int. Apr. 1999;55(4):1476-1485. [pmid: 10201013].
115 Korbet SM, Shih D, Cline KN, Vonesh EF. Racial differences in survival in an urban peritoneal dialysis program. Am J Kidney Dis. Oct. 1999;34(4):713-720. [pmid: 10516354].
116 Perl J, Wald R, Bargman JM, et al. Changes in patient and technique survival over time among incident peritoneal dialysis patients in Canada. Clin J Am Soc Nephrol. Jul. 2012;7(7):1145-1154. [pmid: 22554718].
117 Forbes SH, McCafferty K, Lawson T, Stoby-Fields M, Raftery M, Yaqoob MM. Is lack of suitable housing a barrier to home-based dialysis therapy for patients with end-stage renal disease? A cohort study. BMJ open. 2013;3(2).
118 Rioux JP, Bargman JM, Chan CT. Systematic differences among patients initiated on home haemodialysis and peritoneal dialysis: the fallacy of potential competition. Nephrol Dial Transplant. Jul. 2010;25(7):2364-2367. [pmid: 20360014].
119 Zhang AH, Bargman JM, Lok CE, et al. Dialysis modality choices among chronic kidney disease patients: identifying the gaps to support patients on home-based therapies. Int Urol Nephrol. Sep. 2010;42(3):759-764. [pmid: 20563843].
120 Cafazzo JA, Leonard K, Easty AC, Rossos PG, Chan CT. Patient-perceived barriers to the adoption of nocturnal home hemodialysis. Clin J Am Soc Nephrol. Apr. 2009;4(4):784-789. [pmid: 19339408].
121 Jayanti A, Nikam M, Ebah L, Dutton G, Morris J, Mitra S. Technique survival in home haemodialysis: a composite success rate and its risk predictors in a prospective longitudinal cohort from a tertiary renal network programme. Nephrol Dial Transplant. Oct. 2013;28(10):2612-2620. [pmid: 24078644].
122 Schachter ME, Tennankore KK, Chan CT. Determinants of training and technique failure in home hemodialysis. Hemodialysis international. International Symposium on Home Hemodialysis. Jul. 2013;17(3):421-426. [pmid: 23496376].
123 Tennankore KK, Kim SJ, Chan CT. The feasibility of caregiver-assisted home nocturnal hemodialysis. Nephron. 2012;122(1-2):17-23. [pmid: 23486225].
124 Pauly RP, Maximova K, Coppens J, et al. Patient and technique survival among a Canadian multicenter nocturnal home hemodialysis cohort. Clin J Am Soc Nephrol. Oct. 2010;5(10):1815-1820. [pmid: 20671218].
125 Komenda P, Copland M, Er L, Djurdjev O, Levin A. Outcomes of a provincial home haemodialysis programme--a two-year experience: establishing benchmarks for programme evaluation. Nephrol Dial Transplant. Aug. 2008;23(8):2647-2652. [pmid: 18332070].
126 Klarenbach S, Tonelli M, Pauly R, et al. Economic evaluation of frequent home nocturnal hemodialysis based on a randomized controlled trial. J Am Soc Nephrol. Mar. 2014;25(3):587-594. [pmid: 24231665].
127 Komenda P, Gavaghan MB, Garfield SS, Poret AW, Sood MM. An economic assessment model for in-center, conventional home, and more frequent home hemodialysis. Kidney Int. Feb. 2012;81(3):307-313. [pmid: 21993583].
128 Howard K, Salkeld G, White S, et al. The cost-effectiveness of increasing kidney transplantation and home-based dialysis. Nephrology. Feb. 2009;14(1):123-132. [pmid: 19207859].
129 Gonzalez-Perez JG, Vale L, Stearns SC, Wordsworth S. Hemodialysis for end-stage renal disease: a cost-effectiveness analysis of treatment-options. Int J Technol Assess Health Care. 2005;21(1):32-39. [pmid: 15736512].
130 Malmstrom RK, Roine RP, Heikkila A, et al. Cost analysis and health-related quality of life of home and self-care satellite haemodialysis. Nephrol Dial Transplant. Jun. 2008;23(6):1990-1996. [pmid: 18223263].
131 Kroeker A, Clark WF, Heidenheim AP, et al. An operating cost comparison between conventional and home quotidian hemodialysis. Am J Kidney Dis. Jul. 2003;42(1 Suppl):49-55. [pmid: 12830444].
132 Lee H, Manns B, Taub K, et al. Cost analysis of ongoing care of patients with end-stage renal disease: the impact of dialysis modality and dialysis access. Am J Kidney Dis. Sep. 2002;40(3):611-622. [pmid: 12200814].
133 Goeree R, Manalich J, Grootendorst P, Beecroft ML, Churchill DN. Cost analysis of dialysis treatments for end-stage renal disease (ESRD). Clin Invest Med. Dec. 1995;18(6):455-464. [pmid: 8714789].
134 Chui BK, Manns B, Pannu N, et al. Health care costs of peritoneal dialysis technique failure and dialysis modality switching. Am J Kidney Dis. Jan. 2013;61(1):104-111. [pmid: 22901772].
135 Coentrao LA, Araujo CS, Ribeiro CA, Dias CC, Pestana MJ. Cost analysis of hemodialysis and peritoneal dialysis access in incident dialysis patients. Perit Dial Int. Nov-Dec. 2013;33(6):662-670. [pmid: 23455977].
136 Berger A, Edelsberg J, Inglese GW, Bhattacharyya SK, Oster G. Cost comparison of peritoneal dialysis versus hemodialysis in end-stage renal disease. The American journal of managed care. Aug. 2009;15(8):509-518. [pmid: 19670954].
137 Baboolal K, McEwan P, Sondhi S, Spiewanowski P, Wechowski J, Wilson K. The cost of renal dialysis in a UK setting--a multicentre study. Nephrol Dial Transplant. Jun. 2008;23(6):1982-1989. [pmid: 18174268].
138 Kontodimopoulos N, Niakas D. An estimate of lifelong costs and QALYs in renal replacement therapy based on patients' life expectancy. Health Policy. Apr. 2008;86(1):85-96. [pmid: 17996975].
139 Shih YCT, Guo A, Just PM, Mujais S. Impact of initial dialysis modality and modality switches on Medicare expenditures of end-stage renal disease patients. Kidney Int. Jul. 2005;68(1):319-329. [pmid: 15954923].
140 Sennfalt K, Magnusson M, Carlsson P. Comparison of hemodialysis and peritoneal dialysis--a cost-utility analysis. Perit Dial Int. Jan-Feb. 2002;22(1):39-47. [pmid: 11929142].
141 Stanley M, Cari. The CARI guidelines. Peritoneal dialysis versus haemodialysis (adult). Nephrology. Apr. Suppl 1. 2010;15:S24-31. [pmid: 20591038].
142 Golper TA, Saxena AB, Piraino B, et al. Systematic barriers to the effective delivery of home dialysis in the United States: a report from the Public Policy/Advocacy Committee of the North American Chapter of the International Society for Peritoneal Dialysis. Am J Kidney Dis. Dec. 2011;58(6):879-885. [pmid: 21903316].
143 Young BA, Chan C, Blagg C, et al. How to overcome barriers and establish a successful home HD program. Clin J Am Soc Nephrol. Dec. 2012;7(12):2023-2032. [pmid: 23037981].
144 Nesrallah G, Mendelssohn DC. Modality options for renal replacement therapy: the integrated care concept revisited. Hemodialysis international. International Symposium on Home Hemodialysis. Apr. 2006;10(2):143-151. [pmid: 16623666].
145 Harwood L, Clark AM. Understanding pre-dialysis modality decision-making: A meta-synthesis of qualitative studies. Int J Nurs Stud. Jan. 2013;50(1):109-120. [pmid: 22560169].
146 Tong A, Lesmana B, Johnson DW, Wong G, Campbell D, Craig JC. The perspectives of adults living with peritoneal dialysis: thematic synthesis of qualitative studies. Am J Kidney Dis. Jun. 2013;61(6):873-888. [pmid: 23177729].
147 Tong A, Palmer S, Manns B, et al. The beliefs and expectations of patients and caregivers about home haemodialysis: an interview study. BMJ open. 2013;3(1).
148 Suri RS, Larive B, Hall Y, et al. Effects of frequent hemodialysis on perceived caregiver burden in the Frequent Hemodialysis Network trials. Clin J Am Soc Nephrol. May. 2014;9(5):936-942. [pmid: 24721892].