# INTRODUCTION

Home-based dialysis (defined for this review as in-home hemodialysis [HHD] or peritoneal dialysis [PD]) may offer advantages over in-center hemodialysis (HD) including patient convenience, expanded capacity for VA to deliver fully integrated care to Veterans with end-stage renal disease (ESRD), a reduction in fee-basis costs associated with dialysis, and potentially improved patient quality of life and blood pressure control with greater survival and fewer hospitalizations. Home-based dialysis may also increase ability to care for patients living distant from existing medical centers.1 Home-based dialysis may also allow for more frequent or longer dialysis sessions than conventional (3 times per week for 3 to 4 hours) hemodialysis.2 Disadvantages include the need for a relative or friend to assist (especially with HHD) and the strain that may put on relationships.2

In the United States Renal Data System (USRDS) 2014 Annual Report, it was reported that on December 31, 2012, 402,514 patients (65%) with ESRD were receiving HD, 40,605 (7%) were being treated with PD, and 175,978 (28%) had a functioning graft.3 Renal replacement therapy was received at home by 49,000 patients with 16% receiving HHD and 84% receiving PD. It was noted that 5 times more patients were using HHD in 2012 (N=7,923) than in 2002 (N=1,563).

A 2003 systematic review included RCTs (k=1; reporting only on blood pressure control), comparative observational studies (k=22), or systematic reviews (k=4) of HHD versus in-center HD (hospital-based or satellite unit) published through 2001.^2^ Fourteen studies were conducted in the US. HHD was limited to home hemodialysis using similar equipment and consumables as in-center HD. Sixteen studies (3 systematic reviews and 13 comparative observational studies) reported on quality of life. Although different measures of quality of life were reported, the overall finding was higher quality of life in HHD patients. Of 4 studies that assessed social aspects related to quality of life, 3 found HHD more disruptive for families or that the spouse was less satisfied with the location of the HD compared to in-center HD. The 2003 review also included mortality data from 9 studies – a systematic review published in 1995 and 8 comparative observational studies published from 1978 to 1999. In the 7 studies comparing HHD with in-center HD, survival was generally greater in the HHD groups although some differences were noted depending on the length of follow-up or age at start of RRT. Results were mixed for the 2 studies comparing HHD to HD in free-standing dialysis units; one study reported no difference in survival and the other reported greater survival in the HHD group. The authors noted that HHD patients typically had fewer comorbidities than in-center HD patients. Only one study reported technique survival (the time a person remains on a particular form of RRT) with longer median technique survival in-center HD patients compared to HHD patients.

As the number of Veterans requiring RRT increases, there is a need to expand the Veteran Administration's ability to provide these services by either outsourcing them to the community, expanding in-center dialysis program, or increasing home dialysis (PD or HHD) modalities use among Veterans with ESRD. In order to inform the ESRD program development, the VA commissioned an up-to-date review of the benefits and harms of home-based HD (HHD and PD) versus in-center HD, the benefits and harms of different home-based dialysis modalities, and the predictors of successful home-based dialysis. We focused our review on studies of adults with chronic kidney disease requiring dialysis and comparing home-based and in-center HD. Due to differences in healthcare systems, we further limited the review to studies from North America, Europe, or Australia/New Zealand. We address the following key questions developed with input from topic nominators and a technical expert panel (TEP):

Key Question 1. What are the benefits and harms (ie, all-cause mortality, cardiovascular events, hospitalizations, depression, cognitive impairment, quality of life, conversion to a different type of dialysis, complications related to vascular access, complications of dialysis) of in-home compared to in-center hemodialysis?

1a What are the benefits and harms (ie, all-cause mortality, cardiovascular events, hospitalizations, depression, cognitive impairment, quality of life, conversion to a different type of dialysis, complications related to vascular access, complications of dialysis) of the various modalities of in-home hemodialysis (ie, short daily, nocturnal) compared to conventional hemodialysis?

Key Question 2. What are the benefits and harms (ie, all-cause mortality, cardiovascular events, hospitalizations, depression, cognitive impairment, quality of life, conversion to a different type of dialysis, complications related to vascular access, complications of dialysis) of peritoneal dialysis compared to in-home hemodialysis or in-center hemodialysis?

2a Do results differ depending on whether peritoneal dialysis was the initial therapy or the therapy used following failed in-center dialysis?

Key Question 3. What are the a) health care system, b) provider, and c) patient factors associated with selection of and technique survival for home-based dialysis (including peritoneal dialysis)?

Key Question 4. In the published literature, what are the costs of home hemodialysis or peritoneal dialysis compared to in-center hemodialysis?