# EVIDENCE TABLES

Table 1 REGISTRY STUDIES - Study Characteristics and Survival, Technique Failure, and Transplantation Outcomes for Key Questions 1 and 2

Table 2 TRIALS Study Characteristics and Survival, Technique Failure, and Transplantation Outcomes for Key Questions 1 and 2

Table 3 REGISTRY STUDIES – Interactions

Table 4 TRIALS and OBSERVATIONAL STUDIES - Study Characteristics and Hospitalization, Quality of Life, and Adverse Event Outcomes for Key Questions 1 and 2

Table 5 Study Characteristics and Modality Selection Findings for Key Question 3

Table 6 Study Characteristics and Technique Survival Findings for Key Question 3

Table 7 Study Characteristics and Cost Findings for Key Question 4