# PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes
Yes
Yes
2. Is there any indication of bias in our synthesis of the evidence?
No
No
Yes: Because home hemodialysis is not used frequently in the US, many studies have less than 100 subjects; the arbitrary cut off to discount articles with fewer than 100 subjects may lead to bias against home hemodialysis. | Our decision to exclude studies with fewer than 100 subjects was reviewed and approved by our stakeholders and TEP members. We included RCTs regardless of the number of subjects. Small observational studies are not likely to be informative and controlling for confounding variables is difficult.
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Yes: There are other studies that have evaluated risk factors for technique failure (or technique survival) in PD that are not included; some of these looked at technique failure as a secondary outcome where the primary outcome was mortality and may have been missed if a more detailed review of the articles on risk factors for survival in PD (that did not compare modalities) were not evaluated. The factors assessed in this report appear to be mainly demographics and comorbidity and do not involve dialysis related factors such as infection, transport characteristics, ultrafiltration failure. There are reports using the CANUSA study, those by Davies et al that look at these factors. | We have added additional studies identified in our literature search that reported risk factors for survival in PD only. Regarding the factors assessed in the report, our protocol, approved by stakeholders and TEP members, specified that we would look at health system organizational factors, provider knowledge, and patient factors associated with technique selection and technique success (or failure). Therefore, dialysis factors were outside the scope of the review.
No
Yes: Please see the review below. Articles on home hemodialysis comparison to transplant mortality were not included (Pauly, Nephrol Dial Transplant. 2009 Sep;24(9):2915-9.) as well as smaller articles on caregiver burden and new articles that have been published more recently. | Our Key Questions focused on comparisons of home-based dialysis with other dialysis locations so transplantation was outside the scope of the review. We have updated the literature search (to December 2014). Please see above response regarding small studies.
4. Please write any additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1. It is commented in the review that a greater proportion of individuals on home therapy transfer to in-center HD. What is missing is information on the reason individuals transfer. This could provide more information on factors such as care giver burden.; 2. While registry data shows that PD patients tend to be younger on average. It misses the fact that there is a smaller but significant population of PD patients who are older and who receive PD care with the help of a care giver. This may be more relevant to the VA population. One article that might be relevant with this regards is an analysis by Lobbedez et CJASN 2012 using the French Language Peritoneal Dialysis Registry, where a large proportion of patients received PD with help, most was with family help though they also have a nurse program. For the VA, what might be helpful is if home dialysis support was covered by aid and attendance (if PD or home HD were the option the patient wanted).; 3. It seems odd in the analysis of factors associated with technique failure that dialysis related factors were not assessed- e.g. infection, access failure, ultrafiltration failure etc.; 4. Small point- there appears to be an error on page 40, Lacson paper it was not home based HD, it was home based dialysis, which was predominantly PD. | 1. We reviewed the studies reporting greater proportions with change from HHD to HD. None reported reasons for transfer.; 2. We have added the Lobbedez reference and an additional reference (Smyth 2012) identified in our search that reported on assisted vs independent PD.; 3. Please see above response regarding factors associated with technique failure.; 4. We have clarified that the home-based dialysis in this study was predominantly PD.
This is a scholarly and highly informative systematic review of the comparative effectiveness of in-center versus home dialysis modalities, and the factors that portend the relative success or failure of their adoption. The concise analysis of the quality of the available literature and recommendations for future research are highly instructive. Particularly intriguing are the findings of the association of age, race, gender, and comorbidities with differential success of home RRT adoption, technique survival, and clinical and economic outcomes. The following questions are offered from the specific to the more speculative:; 1. Please clarify what appears to be a contradictory statement on page 8: “Decreased use of HHD or PD was found in more rural facilities… or in high population density zip code areas,… “ Is there a bimodal association of home RRT with domiciliary regional density?; 2. Did any studies examine patient satisfaction as an outcome measure per se or is this another knowledge gap to consider in a research agenda for the VA?; 3. Does the literature specifically report on patient- reported barriers to adoption of home RRT? (ie in contrast to Provider-perceived patient barriers to greater home RRT; 4. For all forms of home RRT – is there any Interaction between likelihood of adoption or technique survival of home RRT based on the following patient characteristics:; a. eGFR at RRT start?; b. Geography of Patient Domicile( rural, ..); c. Type of patient domicile ( SNF versus private home versus other); d. Existence/severity of mental health disorders at RRT initiation; e. Existence of communicable comorbidities (HIV, HCV); f. Type of home RRT technology employed ( CAPD v APD ; Nxstage vs conventional HD equipment); g. For PD: Characteristics of PD transport capacity ( eg high vs low transporter); h. For HHD: low SBP; type of vascular access,; 5. What are the health system factors that associate with home RRT adoption and technique survival?; a. Quantity of pre-dialysis specialty care? Quantity of Predialysis primary care?; b. Use of caregiver/patient economic incentive or economic burden relief?; c. Dedicated transition-to-ESRD team? (ie standardized process/criteria for initiation); d. Provision of comprehensive care in home ( ie all care is home based not just RRT)?; e. Use of telehealth as healthcare support system ?; f. Use of Specialty care staff to provide RRT in home vs Primary care oversight of RRT?; g. Dedicated Home dialysis training centers?; h. Availability of in-center RRT respite centers?; i. Modality of patient education re home RRT? [electronic (video, internet) vs written material,; group education vs 1:1 in-person training]; j. Supply side drivers ( ie available capacity for delivery of in-center RRT); k. Any unique features offered by non-US national healthcare systems that associate with home RRT?; 6. Can table 1.p 20 , table 2 p27, table 5 p 44, and table 3 p84 be amended to include a column for studies reporting effects by health system characteristics and/or mental health disorders on technique failure and mortality associated w in-center HD vs home RRT modalities?; 7. Can a table be created that summarizes the literature reporting on patient, provider, and health system factors that impact home RRT uptake (in contrast to technique survival)?; 8. Based on the literature review, Can a preferred population for home RRT be defined? (Eg age < 65, married, absence of CVD, preferred vasc access ( for home HD),; 9. Based on findings, what resources need to be brought to bear to enable expanded RRT capacity for Veterans through greater uptake/survival of home RRT ?; a. Education: Patient Education tools? Staff training tools?; b. Economic incentives : To patients? To providers?; c. Health system infrastructure: home RRT centers, enhanced home telecommunication; d. Health system redesign: Staffed home RRT delivery? (would require training program for family caregivers ,or community nurses, or expanded dialysis specialty staff pool); 10. Based on literature review, how might VA better serve as a data repository to enhance understanding of relative merit of in-center vs home RRT (eg VA as large national RRT registry,-what missing data would be particularly useful to capture? ) | Thank you.; 1. The study authors do not provide an explanation. However, the findings may not be contradictory. It is likely that facilities in more rural locations do not have resources to support PD while facilities in high population density locations likely have higher percentages of African American patients. The registry studies from the US (Lukowsky 2013, Lievense 2012, Mehrotra 2011, etc.) have shown that PD patients are more likely white. There may also be unmeasured confounding factors, such as socioeconomic status.; 2. One US non-randomized study with 226 patients (Kutner 2000, Table 3) measured satisfaction with care (a scale from the KDQOL instrument). We also summarized results from a systematic review of 39 studies of experiences, beliefs, and attitudes about PD (Tong 2013). Nine studies were from the US. There does appear to be a knowledge gap around patient satisfaction, particularly for HHD, and we have added this to the “Research Gaps” section.; 3. Three studies (from Europe, the UK, and Canada) included patient-reported barriers to PD (Keating 2014, Chanouzas 2012, Maaroufi 2013) and two studies from Canada included patient-reported barriers to HHD (Zhang 2010, Cafazzo 2009).; 4. We have added bullet points in the executive summary and full report to highlight the patient, facility, and provider factors associated with home-based dialysis selection and technique survival that we identified in our literature search.; 5. See #4; 6. The requested information is not available.; 7. See #4; 8. The preferred population would be those who have the longest technique survival. However, due to likely selection bias in the reported studies, it is not possible to conclude who is best suited.; 9. This is a complex question with little evidence to support decision making. The available evidence is from observational studies. It appears that increased uptake is associated with comprehensive pre-dialysis education, facilities with a larger volume of patients (suggesting perhaps one program per network), and caregiver support. There is no evidence that telehealth capability increases uptake but there may be parallels with caregiver support.; 10. A VA dialysis cohort could address a number of deficiencies in the existing data. A survey of all patients starting dialysis could provide information about factors influencing modality selection. Patients could then be surveyed periodically to assess quality of life and caregiver burden, comparing home-based and in-center modalities. Other outcomes of interest could also be captured.
Title: VAESP-D-15-00001 General Comments: This is a systematic review of the literature comparing home dialysis modalities to in-center dialysis regarding benefits and harms. The authors evaluated randomized controlled trials, and observational studies with at least 100 subjects. The review is extensive, but the review suffers from several concerns listed below. Major Concerns:; 1. The authors limited inclusion of studies that were greater than 100 subjects. The authors should consider studies with 50+ patients at least for home hemodialysis (HHD), since most HHD programs in the United States (US) have been small prior to 2006.; 2. There are several newer references that have been published recently regarding nocturnal dialysis outcomes from the Frequent Hemodialysis network that compare nocturnal dialysis to in-center dialysis and more frequent dialysis at home. In particular, there is an article on caregiver burden and nocturnal HHD that the authors may want to include (Clin J Am Soc Nephrol. 2014 May;9(5):936-42 ).; 3. The authors state that most evidence from registry is of high potential for bias and of low quality. There has never been a large randomized trial of home dialysis versus in-center dialysis. Given that there is potential for bias due to patient characteristics, observational studies that attempt to adjust for potential bias by adjustment or study design (case-control), may give useful information, although not as high quality as a randomized controlled trial.; 4. The authors do not include information regarding mortality comparing home dialysis to transplantation, which is another outcome that should be considered, given the potential bias of patient selection for in-center vs. home hemodialysis or PD (Pauly et al, Nephrol Dial Transplant. 2009 Sep;24(9):2915-9.).; 5. The authors state in the executive summary that “However, the applicability of these findings to the Veteran population may be limited. HHD and PD patients typically were younger and with fewer comorbidities than likely seen in Veterans”, which seems to be an overstatement given the paucity of the data. Other countries, such as Australia/New Zealand and Canada have elderly patients with comorbid conditions preferentially on home dialysis therapies. This seems that it may be a bias of the authors against home dialysis modalities!; 6. Catheter related infections and home dialysis. New data has emerged regarding risks from observational studies (Hemodial Int. 2015 Feb 3. doi: 10.1111/hdi.12245. [Epub ahead of print).; 7. The sections of the review should have bullet points at the end that summarize the findings. The executive review has no references at all. References could be enumerated and included.; 8. Recent findings evaluate mortality between HHD and PD patients that the authors should consider (PLoS One. 2014 May 7;9(5):e96847. doi: 10.1371/journal.pone.0096847. eCollection 2014.).; 9. Many of the randomized trials were short term (6-12 months), thus is no long-term follow up of RCTs, which should be stated where appropriate.; 10. The entire review is too long. The authors should try to shorten and place more information in tables for comparison. | 1. See response above regarding sample size of included studies.; 2. We did not include results from the FHN nocturnal trial because the 6 times/wk and 3 times/wk groups were both largely treated at home. The caregiver paper cited (Suri 2014) provides only an indirect comparison of home vs in-center HD caregiver burden but has been included in the Discussion section of the review.; 3. We agree that a large randomized trial of HHD vs HD is not likely. We report the results from the observational/registry studies including the adjusted outcomes.; 4. See response above regarding the comparison of HHD to transplantation.; 5. We have modified the Applicability section.; 6. We have added this study (Xue 2015).; 7. We have attempted to improve the readability of the review. We typically do not include references in the Executive Summary.; 8. We have added this reference (Marshall 2014) along with others identified in our updated literature search.; 9. We reviewed our reporting of the RCTs to confirm that length of follow-up was presented.; 10. As noted above, we have attempted to improve the readability of the review.