# SEARCH STRATEGY

Database: Ovid MEDLINE(R)
1. hemodialysis, home/ or Peritoneal dialysis/
2. ((hemodial$ or haemodial$ or peritoneal dial$ or HHD or NHHD) adj5 (home$ or in-home or out-center$ or out-centre$ or self-admin$ or self-manag$ or self-care or self-treatment$)).mp
3. renal dialysis.mp. or Renal Dialysis/ or exp Kidneys, Artificial/ or haemodialysis.mp. or hemodialysis.mp.
4. (home$ or in-home or out-center$ or out-centre$ or self-admin$ or self-manag$ or self-care or self-treatment$).mp.
5. 3 and 4
6. 1 or 2 or 5
7. exp Renal Insufficiency, Chronic/ or exp Kidney Failure, Chronic/ or (end-stage kidney or end-stage renal or endstage kidney or endstage renal).mp. or (ESKD or ESKF or ESRD or ESRF).mp.
8. 6 and 7
9. limit 8 to (english language and yr=“1995 -Current”)
10. limit 9 to “all child (0 to 18 years)”
11. limit 10 to “all adult (19 plus years)”
12. 10 not 11
13. 9 not 12
14. Randomized controlled trials as topic/
15. Randomized controlled trial/
16. Random allocation/
17. Double blind method/
18. Single blind method/
19. Clinical trial, phase iii.pt.
20. Clinical trial, phase iv.pt.
21. Controlled clinical trial.pt.
22. Randomized controlled trial.pt.
23. ((singl$ or doubl$ or treb$ or trip$) adj (blind$3 or mask$3)).mp.
24. Random$ allocat$.mp.
25. (allocat$ adj2 random$).mp.
26. or/14-25
27. Meta analysis/
28. Meta analys$.mp.
29. (systematic adj (review or overview)).mp.
30. meta analysis.pt.
31. or/27-30
32. exp cohort studies/ or (cohort adj (study or studies)).tw. or Cohort analy$.tw. or (Follow up adj (study or studies)).tw. or (observational adj (study or studies)).tw. or Longitudinal.tw. or comparative study/ or follow-up studies/ or prospective studies/ or cohort.mp. or compared.mp. or multivariate.mp. or Case-Control Studies/ or (case control or case-control).mp.
33. 13 and 26 [RCTs/CCTs]
34. 13 and 31 [SRs/MAs]
35. 13 and 32 [cohort/case-control]
36. 35 not (33 or 34) [cohort/case-control not already in lists for RCTs/CCTs/SRs/MAs]