# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1

What is the evidence about the existence and magnitude of disparities in joint replacement surgery in VA? How does this compare to published studies from non-VA US populations?

Data supporting existence of disparities in joint replacement surgery in VA are not very robust because they come from just three studies, two of which focus on racial disparities and one of which focuses on gender disparities. The magnitude of the racial disparities in VA as documented in these studies is about the same as the magnitude based on more extensive data from non-VA US populations (about 1.5-3 fold). The quality of evidence for this conclusion is low, based on sparseness and age of data. Thus we expect further research both into racial and gender disparities, to have an important impact on our estimate of the magnitude of disparities.

The literature on racial disparities in total joint replacement outside the VA is more robust than within the VA. Studies of non-VA US populations consistently find that black patients receive fewer TKR operations than whites, and men receive fewer TKR operations than women. The quality of evidence for this conclusion is high; thus future research is unlikely to change our confidence about the estimate of effect. However, future research is still necessary to evaluate these disparities over time and assess whether they are increasing or decreasing.

There are fewer studies that examine whether differences in TKR rates represent true disparities based on clinical need. Those that have examined this issue conclude in general, but not consistently, that there are disparities based on clinical need between blacks and nonblacks. The quality of evidence for this conclusion is moderate. Further research is likely to affect our confidence in the estimate of disparities and may change the estimate.

Data about differences in utilization and disparities for total hip replacement in both non-VA US and VA populations are scant, and no conclusions can be drawn. The quality of evidence is therefore very low.

Data about differences in utilization for other races (Hispanic, Asian) are scant, and no conclusions can be drawn. The quality of evidence is therefore very low.

### Key Question #2

What is the evidence about the patient level, provider level, and system level factors that contribute to disparities in joint replacement surgery in VA? How does this compare to published studies from non-VA populations?

Only three studies combine both VA and non-VA patients and examine racial disparities in joint replacement, but they are not able to directly compare actual disparities across VA and non-VA sites. In these studies, there were no racial differences in clinical appropriateness for TJR or differences in perceived arthritis severity or susceptibility for worsening. African American patients were less likely than whites to perceive benefits of and more likely to recognize barriers to TJR. There was no difference in clinical appropriateness for patients at a county hospital compared with patients at a nearby VA. Studies found that County hospital patients were nearly 3-fold more likely to be referred to a surgeon compared with VA patients, but this association was not significant when self-reported referral data were used. The quality of evidence for this conclusion is low because all data came from a single cohort, and replication of the results in other patient populations is needed in order to have stronger confidence in the conclusion.

Evidence about the patient-, provider-, and system- level factors that contribute to disparities in joint replacement surgery in the VA comes from a series of small studies recruiting patients from one or two VA medical centers. The studies find generally that black patients, compared with whites, have lower expectations about the effectiveness of joint replacement, less familiarity with the procedure, and may be more likely to view prayer and other techniques as useful for managing arthritis pain. There is some evidence that blacks may be less likely to be referred to specialists for joint replacement or to have TJR recommended by a specialist; however, some of these differences may be explained by patient preferences. One study examining communication between patients and orthopedic surgeons in the VA found little difference by race.

Although the individual studies are of high quality, the overall quality of evidence for the above conclusions is low because the studies were small and limited to a few sites. It is also likely that further research into important mediators (such as patient preference) and research with different patient cohorts will have an important impact on conclusions about the reasons for these joint disparities. The age of the data is also a limiting factor: a majority of the studies come from patient cohorts recruited over 10 years ago, and 8 of those studies come from a single VA medical center.

Data about reasons for disparities for other races (Hispanic, Asian) are scant, and no conclusions can be drawn. The quality of evidence is therefore very low.

Evidence in non-VA settings suggests that minority patients (African Americans being the most studied) may have less knowledge about joint replacement surgery, perceive fewer health benefits, and have greater fear about the surgery, similar to findings within VA. These patients may be less likely to be referred to a surgeon and are less likely to consider surgery. When they do present for surgery, African Americans have more advanced disease. Disease severity, socioeconomic factors, or degree of comorbidities do not appear to account for all of these differences. Minority patients may be less likely to be treated in high volume centers or by high volume providers, which is a system-level factor that has not been studied within VA.

### Key Question #3

What is the evidence regarding VA or non-VA interventions to reduce disparities in joint replacement surgery?

There has been only one published VA study of an intervention to improve disparities. It focused on expectations and examined only total knee replacement. It found that, after watching an informational video, African Americans, but not Caucasians, had statistically significant improvements in their expectations for pain and function post-operatively. Other potential causes of disparities have not been the subjects of interventions, and no study has yet assessed changes in the actual delivery of joint replacement surgery.

The quality of evidence for this key question is very low, due to sparseness of data; thus any estimate of effect is uncertain.

## LIMITATIONS

### Publication Bias

Our literature search procedures were extensive and included canvassing experts from academia regarding studies we may have missed. It was not possible to conduct formal tests for publication bias, but even with such tests it is not possible to exclude the possibility that such bias exists. Therefore, readers are cautioned about this possibility.

### Study Quality

An important limitation common to systematic reviews is the quality of the original studies. We did not identify any randomized studies. For non-randomized studies, we adapted from the Newcastle Ottawa Scale those criteria most applicable to our purposes, namely items about the representativeness of the enrolled population, the potential for misclassification bias in the identification of race, gender, or receipt of procedure, and the response rate or follow-up rate. Several studies that used non-VA data were based on nationally representative populations. This was in general not the case for the VA studies, which tended to be from one or two institutions.

### Types of Factors Evaluated

Almost all studies of factors potentially contributing to disparities were of patient or provider-level factors. System-level factors that are amenable to quality improvement activities, such as waiting times, have rarely been addressed.

### Applicability of Findings to the VA Population

For the VA studies we assessed, the results are directly applicable to the VA population. However, as noted, the studies were generally restricted to only one or two centers.

### Types of Disparities Represented in the Literature

While our search for disparities was broad, we identified a body of literature that deals primarily with disparities in race and gender. Other potential disparities, such as educational and socioeconomic factors, have been largely unstudied.

## RECOMMENDATIONS FOR FUTURE RESEARCH

More research is needed in VA. The one national study of disparities in joint replacement in VA 27 contain data from over 10 years ago and focused on knee replacement only, and the second uses more recent data26 but includes individuals referred to orthopedic clinics at two VA (with borderline statistical significance for the finding of racial disparities after statistical adjustment). Most VA second-generation studies are from limited samples and are over ten years old. The reviewed VA studies were well-designed, but a better and more current understanding of the reasons for the observed disparities is needed in order to design third-generation intervention studies that are most likely to succeed. In addition, with the increasing number of women and Hispanic veterans, planning now to better understand their potential need for TJR in the future is warranted.

In specific, VA could consider assessing the current utilization of TJR in a national or representative sample of veterans and VISNs, to first establish the magnitude of any differences in utilization in TJR between male and female veterans and those of different races. Second, presuming current data confirm the presence of different utilization rates, an in-depth examination should be performed of the degree to which these may be confounded by other factors, in other words asses “need” for joint replacement. Third, presuming that, even after adjusting for confounders, there still exists differential utilization among Veterans of different gender and ethnicity with the same “need,” mixed-method types of research will be necessary to help establish the causes and barriers that are contributing to this disparity. This research should examine, in addition to patient and provider level factors, the kinds of system level factors that are particularly amenable to the types of quality improvement initiatives that VA can implement well, due to its organizational structure. Lastly, based on the results of all the above, VA should test interventions to diminish disparities, addressing the need for third generation work, and implement those found effective nationally.