# RESULTS

## LITERATURE FLOW

Our literature search identified 284 titles and abstracts from the electronic search, and one additional article from reference mining, for a total of 285 references. We excluded 155 titles as being clearly irrelevant. We conducted an update search after peer review, which yielded 12 new articles, with an additional two articles from reference mining, bringing the total up to 299 references. We retrieved 144 full-text articles for further review and excluded another 70 references for various reasons (see Figure 3). We identified a total of 74 references for inclusion in the current review. We grouped the studies by key question, type of disparity, and whether the patient population was of VA or non-VA origin. Figure 3 details the flow of articles from citations to the number of references informing each of the key questions.

Figure 3 Literature Flow

*Key question categories were not mutually exclusive, meaning some of the 22 “KQ1” studies were also part of the 35 “KQ2” category.

**The 28 articles addressing gender disparities in non-VA populations were not included in the tables or report.

## DESCRIPTION OF EVIDENCE

Studies of racial disparities in joint replacement that focus on VA patients are clustered around 7 patient cohorts (see Table 2). Two of these studies report on rates of receipt of total joint replacement (first generation studies26, 27); the remaining are second generation studies attempting to identify mechanisms underlying the known disparities. One study28 includes Hispanic ethnicity; otherwise the studies focus on disparities between blacks and whites.

Table 2 Cohort description

Author/year | Study Cohort
Hausmann, 2010^26^ | Orthopedic Clinics Pittsburgh and Cleveland
Hausmann, 2011^29^ | Orthopedic Clinics Pittsburgh and Cleveland
Ang, 2009^30^ | VA+ County Hospital in Indiana
Ang, 2009^31^ | VA+ County Hospital in Indiana
Ang, 2008^32^ | VA+ County Hospital in Indiana
Jones, 2008^33^ | VA Philadelphia and Pittsburgh
Groeneveld, 2008^34^ | VA Philadelphia and Pittsburgh
Jones, 2005^27^ | National VA Patient Treatment Files
Borrero, 2006^35^ | National VA Patient Treatment Files
Ibrahim, 2005^28^ | VA National Surgical Quality Improvement Program (NSQIP)
Lopez, 2005^36^ | Cleveland VA Primary Care Clinics
Ang, 2003^37^ | Cleveland VA Primary Care Clinics
Ibrahim, 2003^38^ | Cleveland VA Primary Care Clinics
Ibrahim, 2002^39^ | Cleveland VA Primary Care Clinics
Ibrahim, 2002^40^ | Cleveland VA Primary Care Clinics
Ibrahim, 2002^41^ | Cleveland VA Primary Care Clinics
Ibrahim, 2002^42^ | Cleveland VA Primary Care Clinics
Ibrahim, 2001^43^ | Cleveland VA Primary Care Clinics
Weng 2007^44^ | VA Greater Los Angeles Ambulatory Care

In addition we identified 22 non-VA first generation studies, one of which was a systematic review.20 There were 21 non-VA second-generation studies. There was only one third-generation study, which was of VA patients. For gender disparities, we identified 29 non-VA studies and one VA (first-generation) study. Only the VA study is discussed in this report. The evidence tables present details of each included study (see Appendix F).

## KEY QUESTION #1 What is the evidence about the existence and magnitude of disparities in joint replacement surgery in VA? How does this compare to published studies from non-VA US populations?

### VA Data

Three first-generation studies report on disparities in receipt of total joint replacement in VA settings. Two studies used national data; one was based in two institutions. All three studies were judged to have population-based or otherwise representative patient samples. Race was identified using self-report in one study and administrative data in the other two. In all three studies, administrative or medical record data were used to determine if a procedure had been performed. In all three studies, response rate or adequacy of follow-up were not applicable (see Appendix F, evidence table 1).

One study examines a local cohort of 457 veterans seen between 2005-2008;^26^ another uses national VA patient treatment files from 1999-2001 to report on rates of receipt of knee replacement (only) among 260,856 veterans.27 Hausmann et al.26 recruited patients immediately before and after their orthopedic surgery clinic visit at two large VA hospitals (Pittsburgh and Cleveland) between 2005 and 2008. The primary outcome was whether patients received a recommendation for TJR from the surgeon, as determined by electronic medical record review. The secondary outcome was receipt of TJR at the VA within 6 months of study enrollment. The odds of receiving a TJR recommendation were lower for blacks than for white patients of similar age and disease severity (OR 0.46, 95% CI 0.26-0.83). This difference, however, was no longer significant after adjusting for patient preference for TJR (measured using a single item question). The adjusted odds of actual receipt of TJR were lower for blacks than for whites, although the results did not reach statistical significance (OR 0.41, 95% CI 0.16-1.05).

In the second first-generation study, Jones et al.27 examine 260,856 patients with osteoarthritis (based on ICD-9 code 715.x) from the national VA patient treatment files in 1999 with 2-year follow up to determine rates of TKR. In the final statistical model, adjusting for age, gender, and Charlson comorbidity (without adjustment for disease severity), black patients were less likely than whites to have received TKR (OR 0.72, 95% CI 0.65-0.80).

One of the three studies reporting on disparities in receipt of TJR in VA settings assessed gender disparities.45 Borrero and colleagues analyzed a national sample of 1,986,093 VA patients aged 50 years or older (1,923,524 male, 44,569 female) in the VA National Patient Care Database during fiscal year 1999. In this cohort, 172 (0.4%) women and 5,198 (0.3%) men received TKR (P<.001), and 91 (0.2%) women and 2,618 (0.1%) men received THR (P=.001). The odds ratios for receipt of TJR was 1.4 for women compared to men, which demonstrated the statistically significantly higher rates of TKR and THR in women. However, after adjusting for the presence of OA, there was no longer any significant difference in odds of receipt of TJR. The authors noted that women have a higher prevalence of OA-related disability, and additionally adjusted for this in an OA subcohort of 329,461 patients (319,924 male, 9,537 female), which consisted of patients with a diagnosis of OA using the ICD-9-CM code. Within this subcohort, there were no differences by gender: 153 (1.6%) women and 4,638 (1.5%) men had TKR, and 73 (0.8%) women and 2147 (0.7%) men had THR. The authors suggest that an important factor in understanding gender differences in TJR is the difference in OA prevalence between men and women.

### Non-VA Data

The literature on racial disparities in total joint replacement outside the VA is more robust than within the VA. However, we found only one systematic review on the topic of disparities in total knee replacement (Kane et al.20). An additional review on the epidemiology of knee and hip arthroplasty was identified.19 Its focus was not on disparities, nevertheless data on differences in utilization by gender and race was reported.

In 2007, Kane et al.20 published the results of a systematic review examining disparities in total knee replacement performed by the Minnesota Evidence-Based Practice Center and commissioned by the Agency for Healthcare Research and Quality. The review was presented to experts at an NIH Consensus Conference on Total Knee Replacement in December 2003. In discussing the limitations of the literature, the authors mention that some of the studies address rates of procedure use without paying attention to the size of the population at risk (patients with severe symptomatic knee/hip OA who might have an indication for TJR); this limitation is worth noting as rates of use are presented below.

The authors limited their search to English language articles between 1995-2003 and excluded studies with less than 100 observations; of the 176 references that they identified, only 4 met the inclusion criteria. The authors added another 3 studies from reference mining, for a total of 7 studies. The 7 studies primarily use Medicare national claims to examine rates of disparities, with the exception of two studies: one examined a community cohort of elderly patients with arthritis, and the other examined a cross-sectional survey of people age 55 or older in Ontario, Canada. Each of the studies finds the highest rates of TKR use in whites compared with nonwhites. Most of these studies examining gender disparities found that women were more likely to receive joint replacement than men; in one study,46 women were less likely to receive joint replacement after adjusting for presence and severity of arthritis. The results of the Kane and colleagues review indicate that there are racial/ethnic and gender disparities in the receipt of TKR in the United States.

A recent systematic review by Singh19 focused on studies of the incidence and prevalence of knee and hip arthroplasty. Included in this review were data from six studies, three of them from the United States, all reporting differences in utilization rates by gender, ethnicity, or both.

Our search found nine overlapping references that will not be discussed further, as they were included in Kane or Singh.8, 11, 12, 16, 47-51 Although not discussed here, they still appear in the evidence tables (see Appendix F).

More recent studies document the continued existence of racial/ethnic disparities in TKR. Jha et al.52 describe rates of both TKR and THR among the Medicare fee for service population, this time comparing 1992 to 2001. In their analysis, they compare blacks vs. nonblack patients in Medicare and stratified the analysis by gender. In each analysis, women had higher age-adjusted rates of procedure use than men, and nonblacks had higher rates than blacks. In 2001, nonblack men had a rate of 5.05/1000 population for TKR, compared with 1.85 for black men. Among women, rates of TKR per 1000 population were 6.6 among nonblacks and 5.1 among blacks.

In another analysis of Medicare (one of the few including Hispanic ethnicity) from 2000, Skinner et al.53 compare rates of TKR adjusted for age and income and find that, compared with white men, the odds ratio for receipt of TKR for black men was 0.36 (0.34,0.38), for Hispanic men 0.67 (0.62-0.73), and for Asian men 0.28 (0.24,0.32). White women and Hispanic women were more likely and as likely, respectively, as white men to receive TKR.

Another study looked at Medigap coverage and found disparities in receipt of joint replacement based on whether patients lived in a high, standard or low minority area. Patients were defined as living in a high-minority area if 60% or more of the population in their zip code was in one of the nonwhite minority groups. Low minority area was defined as 15% or less of residents in one of the non-white minority groups. Patients living in high minority areas were 20% less likely to undergo a hip or knee replacement as those who resided in low minority areas.54

Four additional studies, using older data and non-Medicare data sources, also found significant disparities. In an analysis using the Nationwide Inpatient Sample from 1990-2000, Jain et al.55 examine the percentage of all TKRs performed on black patients vs. white patients; however, the overall rate of TKR among blacks and whites is not known, and 27% of race data was missing. They found that the percentage of all TKRs performed on black patients has increased from 1990-1993 (4.2% black), to 1994-1998 (5.9% black), to 1998-2000 (6.5% black).

Bang also used the Nationwide Inpatient Sample, but from 1996-2005, and found that non-white groups had lower odds of THA and TKA compared with whites.56 All racial minority groups were 23% to 64% less likely to undergo arthroplasties. Racial disparities were larger than income disparities, and racial disparities were not confined to elderly or to low-income.

Hanchate et al.57 describe rates of knee replacement in the Health and Retirement Survey (HRS) from 1994-2004. They find no racial/ethnic differences in rates of TKR among women after adjusting for economic factors, including insurance, income, assets, and age. However, they find that black men are significantly less likely than white women to receive a TKR (OR 0.56 (0.33-0.95), although the difference is no longer statistically significant when the sample is limited to those with self-reported arthritis. There were no disparities comparing Hispanics and whites.

Finally, an analysis using hospital discharge data from Connecticut from 1996-1998, Olson and Foland58 examined rates of TKR; the analysis did not account for rates of severe OA, or preferences or need for TKR. They found that the age adjusted rates per 100K discharges for TKR was highest for black women (115.8, 95% CI 103.9-127.7) and lowest for black men (44, 34.9-68.9) and Hispanic men (16.9, 10.1-23.8) and women (47.5, 37.8-57.2). White women had rates of 84.9 (82.4-87.4) and white men 66.5 (63.9 -68.9).

The Kane review focused on total knee replacement. There are no systematic reviews specifically examining racial/ethnic disparities in total hip replacement (THR). Many of the studies examining hip replacement use data that are quite old. Jha et al.52 included hip replacement in their analyses of Medicare data and found that in 2001, nonblack men had a rate of THR of 2.60/1000 population compared with 1.08/1000 for blacks. Among women, rates per 1000 population in THR were 3.33 for nonblacks and 1.86 for blacks. Using data from 1997-2001 hospital discharge records from two states included in the HCUP, Basu and Mobley59 found no difference in the likelihood of THR between blacks, whites and Hispanics in either 1997 or 2000, after adjusting for income, urban/rural, distance from hospital, and social isolation. They did not adjust for severity of arthritis.

Two older studies (from the 1980s) using hospital discharge records from Hawaii60 and California14 examined rates of THR; the studies did not include information about the need for the procedure. Oishi et al.60 found no differences in rates of THR among whites and Asians for those under age 50, but lower rates among Asians for those over age of 50. Giacomini14 found no statistically significant difference in THR rates after adjusting for insurance status, age and comorbidities between whites, Hispanics, and blacks; however, Asians had lower odds of THR (0.47, 0.29-0.77).

One study outside the VA examined disparities in joint replacement surgery, combining TKR and THR. Francis et al.61 reported rates of TKR/THR in 2005 Medicare data, comparing rural and urban beneficiaries. They found that nonwhites are less likely than whites in rural areas to receive joint replacement (OR 0.69, 0.66-0.71); the disparity is more pronounced in urban areas. African Americans had lower odds than whites for receipt of the procedures in rural areas (OR 0.68, 0.65-0.71). There were no differences in adjusted rates of joint replacement for Hispanic vs. white in rural areas, but there were differences in urban areas (OR 0.62).

Finally, in one of the few studies that examined rates of TKR/THR among those in need (based on difficulty walking, joint pain, stiffness, or swelling),62 African American patients in the Health and Retirement Study (HRS) from 1998-2004 were less likely to receive joint replacement than whites (OR 0.34 (0.17-0.66)). The higher rate of joint replacement in women compared to men was appropriate, based on their assessment of need.

### Summary of Findings

Data supporting existence of disparities in joint replacement surgery in VA are not very robust because they come from just three studies, two of which focus on racial disparities and only one of which focuses on gender disparities The magnitude of the racial disparities in VA as documented in these studies is about the same as the magnitude based on more extensive data from non-VA US populations (about 1.5-3 fold). The quality of evidence for this conclusion is low, based on sparseness and age of data. Thus we expect further research, both into racial and gender disparities, to have an important impact on our estimate of the magnitude of disparities.

The literature on racial disparities in total joint replacement outside the VA is more robust than within the VA. Studies of non-VA US populations consistently find that black patients receive fewer TKR operations than whites, and men receive fewer TKR operations than women. The quality of evidence for this conclusion is high; thus future research is unlikely to change our confidence about the estimate of effect. However, future research is still necessary to evaluate these disparities over time and assess whether they are increasing or decreasing.

There are fewer studies that examine whether differences in TKR rates represent true disparities based on clinical need. Those that have examined this issue conclude in general, but not consistently, that disparities in joint replacement between blacks and non-blacks persist after adjusting for clinical need. The quality of evidence for this conclusion is moderate. Further research is likely to affect our confidence in the estimate of disparities and may change the estimate.

Data about differences in utilization and disparities for total hip replacement in both non-VA US and VA populations are scant, and no conclusions can be drawn. The quality of evidence is therefore very low.

Data about differences in utilization for other races (Hispanic, Asian) are scant, and no conclusions can be drawn. The quality of evidence is therefore very low.

## KEY QUESTION #2 What is the evidence about the patient level, provider level, and system level factors that contribute to disparities in joint replacement surgery in VA? How does this compare to published studies from non-VA populations?

### Direct Comparison of VA and Non-VA Patients

Three studies include both VA and non-VA patients and examine racial disparities in joint replacement, thus potentially providing the most direct comparison between VA and non VA.30-32 These three papers, however, report on the same cohort of patients and are not able to compare actual disparities across VA and non-VA patients, since site of care is used primarily as an adjustment variable. Patients were collected from one prospective study of primary care clinics that referred patients to a VA medical center (serving Indiana and surrounding states) and from patients in a non-VA County hospital, which was near the VA, with primary care network and community health care centers (Indianapolis). Race was self-reported.

The primary outcomes of interest were racial disparities in clinical appropriateness, perceived health beliefs of TJR, and referral to an orthopedic surgeon. Outcomes were assessed using the medical record and self-report. The sample size varied slightly between reports, ranging from 676 to 691. Approximately 90% of eligible subjects participated. The patient cohort comprised 38% African Americans (AA) and 72% whites, all of whom had at least moderate osteoarthritis. Eligibility criteria included age (>50 y/o), radiographic evidence of osteoarthritis, and Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) summary score >=30. There were differences in the racial distribution of patients by recruitment site: 64% of the African American patients and 30% of whites were recruited from the county hospital

Results showed no differences in clinical appropriateness for TJR between the racial groups: (appropriate for TJR: 25.5% AA versus 29.4% whites; inappropriate: 74.5% AA versus 70.6% whites; P=0.3).31 Multivariate regression confirmed that race did not predict clinical appropriateness (OR=1.2 [0.8–1.8]; P=0.3). Clinical appropriateness was determined using an algorithm based on 5 variables: adequacy of medical management, WOMAC pain severity, WOMAC functional limitation, age (50–70 years or >70 years), and medical comorbidity. Patients were categorized as appropriate, uncertain, or inappropriate for TJR. Appropriate represented a patient who was severely symptomatic (pain and function) despite medical management, and could undergo surgery with acceptable risk. This validated algorithm show that appropriateness was associated with better health-related quality of life following TJR. There was no difference in clinical appropriateness between county and VA patients (28.8% versus 27.2%, P=0.6).

A similar analysis of 684 patients from this cohort looked at the association of race with health beliefs and barriers to TJR.32 This outcome was assessed using the modified Arthritis-related Health Belief Instrument (AHBI), based on the Health Belief Model. AHBI reports 4 themes: perceived arthritis severity, perceived susceptibility for arthritis to worsen, perceived benefits of arthroplasty, and perceived barriers to arthroplasty. This analysis identified differences in health beliefs and barriers to TJR. African American patients were less likely than whites to perceive benefits of TJR (OR=.60 [.42-.86]; P=.005) and more likely to recognize barriers to TJR (OR=1.7 [1.18-2.44]; P=.004). The analysis did not find any racial differences in perceived arthritis severity or susceptibility that arthritis would worsen. Recruitment site was predictive of perceived benefits of TJR: County patients were less likely than VA patients to perceive benefits of TJR (OR=.45 [.23-.89]; P=0.02). Hospital site (county versus VA) did not predict perception of barriers to THR (OR=1.38 [0.71-2.66]; P=.33). Race and hospital site interactions were not significant.

The third study assessed the same patient cohort (n=676); the primary outcome was referral to an orthopedic surgeon.30 Race, clinical appropriateness, and health beliefs were included in the analyses. Neither race (HR=1.39 [0.94–2.05]; P=0.1) nor any of the four health belief themes (HR range 0.99 to 1.05) predicted referral to a surgeon. However, clinical appropriateness did predict referral (HR=1.95 [1.15-3.32]; P=0.01). Regression models controlled for recruitment site (county versus VA). In a univariate analysis, non-VA patients were more likely to be referred to an orthopedic surgeon than were VA patients (60.5% compared with 39.5%, P<0.0001). Multivariate regression showed that county patients were more likely (HR=2.7 [1.4 –5.1], P=0.0026) than the VA patients to be referred to surgery. Interactions of race with hospital site, health beliefs, and clinical appropriateness were not significant.

### Summary of Findings

Only three studies combine both VA and non-VA patients and examine racial disparities in joint replacement, but they are not able to directly compare actual disparities across VA and non-VA sites. There were no racial differences in clinical appropriateness for TJR or differences in perceived arthritis severity or susceptibility for worsening. African American patients were less likely than whites to perceive benefits of and more likely to recognize barriers to TJR. There was no difference in clinical appropriateness for patients at a county hospital compared with patients at a nearby VA. Studies found that County hospital patients were nearly 3-fold more likely to be referred to a surgeon compared with VA patients, but this association was not significant when self-reported referral data were used. The quality of evidence for this conclusion is low because all data came from a single cohort, and replication of the results in other patient populations is needed in order to have stronger confidence in the conclusion.

### VA Data

Each of the additional studies of joint replacement in VA comes from one of the other 6 patient cohorts, as described above (Table 2). All but one are small studies of patients in either one or two VA Medical Centers; the larger study used NSQIP data.28 Two studies had population-based or otherwise representative sampling of patients; the rest used convenience samples. Race was identified by self report except for the larger study, which used administrative data. Assessment of receipt of the procedure was a criterion that only applied in two of the studies, one using administrative data, the other using medical records. Response rates were not recorded for about half of the studies; in the remainder, response rates were high.

In a majority of cases, the studies focused on patient factors that might explain racial disparities in procedure use, but in a few cases the studies deal with topics that overlap patient, provider, and health system factors as well as the clinical encounter (based on conceptual framework, Figure 2 above).

In one VA cohort, patients aged 50-79 with chronic knee or hip pain and WOMAC score greater than 38 were enrolled from primary care clinics at the Philadelphia and Pittsburgh VA Medical Centers between 2004 and 2006. The first study from this cohort33 examined racial differences in the pain coping strategies for 939 of these patients. This analysis found that, of the various coping strategies, blacks relied more on hoping and praying compared with whites (Beta = 0.74, 95% CI 0.50-0.99), and blacks were more likely to view prayer as helpful (OR 3.38, 95% CI 2.35-4.86) and to have tried prayer (OR 2.28, 95% CI 1.66-3.13) to manage their pain. Groeneveld et al.34 report on a second study using the same cohort to examine racial differences in the expectations of the effectiveness of joint replacement in improving quality of life, measured using a validated survey scale (JRES). After adjusting for disease severity, socioeconomic factors, literacy, and trust, there were small but statistically significant differences in patient expectations, with blacks having lower expectations for both knee and hip OA. The authors note that the clinical and policy significance of these differences is not clear.

Eight of the VA studies on racial disparities in joint replacement come from a cohort of 596 patients from primary care clinics at the Cleveland VA in 1997-2000.^36-43^ Participants in the cohort were approached and asked about their hip/knee pain, and they were eligible for inclusion if they self-identified as white or black, were over age 50, and had at least moderate severity symptoms based on the Lequesne OA Severity Index. Each of the studies (which had considerable overlap in authorship) is described in more detail below. All focus on patient factors underlying joint replacement disparities; two also involve the overlap of patient and provider factors and the clinical encounter.

In the earliest study based on this cohort, Ibrahim et al.43 examined differences in the perceptions of the efficacy of traditional treatments and complementary treatments and self-care practices for osteoarthritis. In adjusted analyses, blacks were less likely to believe that joint replacement was efficacious compared with whites (OR 0.52, 95% CI 0.28-0.98) and were more likely to rely on self-care measures for their arthritis. The same authors published a second study42 that examined differences in the familiarity and knowledge of respondents about joint replacement within the same cohort; black patients were less likely than white patients to be familiar with joint replacement surgery (had ever heard of TJR or had family/friends with TJR or reported a ‘good understanding’ of TJR) and more likely to express concerns about post-operative pain and walking ability.

In a third study from the Cleveland VA cohort41 examining self-assessed quality of life, the same authors found that black race was associated with worsened quality of life; the analyses adjusted for WOMAC score, depression, and other clinical factors. In a fourth study, Ang et al.40 focused on the ‘helpfulness of prayer’ in the treatment of OA and how that belief affected attitudes towards arthroplasty. They found that black patients were more likely than whites to perceive prayer as helpful in the management of their arthritis (OR 2.1, 95% CI 1.19-3.72) and were less likely to consider surgery for severe arthritis pain (OR 0.59, 95% CI 0.34-0.99). The authors suggest that feelings about the helpfulness of prayer among black patients may explain part of the differences found in the rates of TJR among patients with osteoarthritis.

Two of the studies from the Cleveland VA cohort37, 38 describe differences in how pain is perceived between blacks and whites with osteoarthritis. Ang et al.37 examined differences in perceptions of pain and functional disability between blacks and whites at a given level of radiographic severity of arthritis. They found no differences in mean pain and function scores (from the WOMAC). The authors interpret these findings as evidence that differences in perceived symptoms do not explain the observed disparities in joint replacement. Ibrahim et al.38 report on an exploratory factor analysis in a subsample of these patients (300 veterans). They find a different factor structure in descriptions of pain among blacks and whites, and note that these descriptions of pain did not correlate with radiologic stage of disease. They suggest that blacks and whites with chronic joint osteoarthritis describe the quality of their pain differently.

Two final studies from this Cleveland cohort of 596 patients focus primarily on outcomes that involve considerable overlap between patient and provider factors and the clinical encounter. Ibrahim et al.39 report on racial differences in the willingness to consider surgery, familiarity with joint replacement surgery, and outcome expectations among patients with arthritis. Blacks had lower odds of having family/friends with TJR (OR 0.39, 95% CI 0.26-0.61) and lower odds of ever hearing of TJR (OR 0.64, 95% CI 0.37-1.09). They were also more likely than whites to expect a longer hospital course and moderate to severe pain and difficulty walking after TJR. Willingness to consider TJR was assessed using one question: “If your pain were to get severe, would you consider surgery to replace your knee/hip if your doctor recommended it?” After adjusting for demographic characteristics, clinical severity, and familiarity with surgery, blacks were less likely than whites to respond yes (OR 0.53, 95% CI 0.30-0.96). However, after adjusting for outcome expectations, the difference between blacks and whites in willingness to consider TKR was no longer significant (OR 0.86, 95% CI 0.45-1.63). Here the authors suggest that expectations of postsurgical course mediated the differences in willingness to have surgery. Lopez et al.36 examine referrals to specialists and satisfaction with care among this same cohort of patients with knee and/or hip OA. They find that blacks were less likely to view the quality of the primary care relationship as excellent (24.7% vs. 36.3%, p<.01) and less likely to receive a referral to an orthopedic surgeon (17.4% vs. 24.2%); the latter did not reach statistical significance (p = 0.06). In multivariate analyses adjusted for severity of disease, blacks had lower odds of referral to an orthopedic surgeon (OR 0.61, 95% CI 0.36-1.03), although the relationship only approached statistical significance.

Four additional studies using different VA cohorts examine determinants of disparities in joint replacement that overlap between patient, provider, and clinical factors. In the second VA study using national data from the Veterans Administration National Surgical Quality Improvement Program (NSQIP), and the only study including Hispanic veterans, Ibrahim et al.28 report on the differences in outcomes between black, white and Hispanic veterans who undergo hip and knee arthroplasty between 1996 and 2000-6,703 patients and 12,108 patients respectively. They examine rates of risk-adjusted 30-day mortality and rates of both infectious and non-infectious complications. There were no racial/ethnic differences in 30-day mortality, although there were differences in complication rates. Black patients had higher infection and non-infection related complications following knee replacement (RR 1.42, 95% CI 1.06-1.90, and 1.50, 95% CI 1.08-2.10, respectively.) Hispanic patients had a higher risk of infection (but not non-infection) related complications compared to whites (RR 1.64, 95% CI 1.08-2.49). There were no racial differences in hip arthroplasty complications.

Hausmann et al.26, 29 recruited patients immediately before and after their orthopedic surgery clinic visit at two large VA hospitals (Pittsburgh and Cleveland) between 2005 and 2008, and report on two separate studies. In the first,26 the primary outcome was whether patients received a recommendation for TJR from the surgeon, as determined by electronic medical record review. The authors found the odds of receiving a TJR recommendation were lower for blacks than for white patients of similar age and disease severity (OR 0.46, 95% CI 0.26-0.83); however, the difference was no longer significant after adjusting for patient preference for TJR (measured using a single item question). In the second study,29 Hausmann et al. analyzed audio recordings for 402 of the 526 patients in the cohort to examine racial differences in patient-provider communication about treatment of chronic knee and hip osteoarthritis. The authors found very little racial difference in patient-provider communication, including no difference in informed decision-making and no difference in visit length, provider or patient affect, or physician verbal dominance. The only 2 aspects of communication that differed were less discussion of biomedical topics and more rapport-building statements in visits with blacks compared with whites. The authors conclude that their findings argue against the idea that communication differences play a large role in explaining disparities in joint replacement.

Finally, a small pilot study testing an intervention designed to reduce joint disparities in VA44 contains data on baseline racial disparities. (The results of the intervention are described below.) The study included a convenience sample of 102 patients with moderate to severe osteoarthritis (WOMAC >39) recruited from the Greater Los Angeles VA Healthcare System. Baseline expectations about post-TKR outcome were lower for African American patients than for white patients regarding pain and physical function (P= 0.18 and P=0.13, respectively), although the results were not statistically significant. African American patients were also less likely to have ever heard of TKR compared with whites (49% vs. 72%, p=0.02), and less likely to know someone who had TKR (34% vs. 53%, p=0.05). There was no statistically significant difference in willingness to consider surgery at baseline (P=0.12).

### Summary of Findings

Evidence about the patient-, provider-, and system- level factors that contribute to disparities in joint replacement surgery in the VA comes from a series of small studies recruiting patients from one or two VA medical centers. The studies find generally that black patients, compared with whites, have lower expectations about the effectiveness of joint replacement, less familiarity with the procedure, and may be more likely to view prayer and other techniques as useful for managing arthritis pain. There is some evidence that blacks may be less likely to be referred to specialists for joint replacement or to have TJR recommended by a specialist; however, some of these differences may be explained by patient preferences. One study examining communication between patients and orthopedic surgeons in the VA found little difference by race.

Although the individual studies are of high quality, the overall quality of evidence for the above conclusions is low because the studies were small and limited to a few sites. It is also likely that further research into important mediators (such as patient preference) and research with different patient cohorts will have an important impact on conclusions about the reasons for these joint disparities. The age of the data is also a limiting factor: a majority of the studies come from patient cohorts recruited over 10 years ago, and 8 of those studies come from a single VA medical center.

Data about reasons for disparities for other races (Hispanic, Asian) are scant, and no conclusions can be drawn. The quality of evidence is therefore very low.

### Non-VA Data

A number of review articles have been published about reasons for disparities in health care in general and a few about osteoarthritis and pain in particular. Perhaps most notable is the Institute of Medicine report “Unequal Treatment: Confronting Racial and Ethnic Disparities in Health Care.”63 This report concluded, with respect to “Assessing Potential Sources of Disparities in Care,” that:

- A small number of studies suggest that racial and ethnic minority patients are more likely than white patients to refuse care. These studies find the differences in refusal rates are generally small and that minority patient refusal does not fully explain health care disparities.
- Many sources, including health systems, healthcare providers, patients, and utilization managers - may contribute to racial and ethnic disparities in healthcare.
- Bias, stereotyping, prejudice, and clinical uncertainty on the part of healthcare providers may contribute to racial and ethnic disparities in healthcare. While indirect evidence from several lines of research support this statement, a greater understanding of the prevalence and influence of these processes is needed and should be sought through research.

More recent review articles on disparities in general include that of King et al.,64 which expanded somewhat on the IOM review, and Klonoff ,65 which noted that “almost 35% of the national differences in arthroplasty rates for African-American women and almost 95% of the differences for Latino women appear to reflect that African-American and Latino women were more likely to live in areas of the country with lower rates of arthroplasty”. Saha et al.66 reviewed disparities in VA health care and categorized potential causes of disparities as patient medical knowledge and information sources, patient trust and skepticism, patient participation, patient social support and resources, clinician judgment, racial/cultural milieu, and healthcare facility characteristics.

Reviews more specific to joint replacement include a section of a review by Anderson, Green and Payne67 on disparities in pain, which concluded that variability in decision-making in primary care as well as delay in surgical referral contributed to disparities in pain and post-operative outcomes; and a review by Allen68 on racial and ethnic disparities in osteoarthritis phenotypes, which concluded that knee osteoarthritis may be more common in African-Americans than in Caucasians in the United States, and that pain and problems with physical functioning is greater for African-Americans than for Caucasians with knee osteoarthritis.

Set against this general background, we identified 20 studies of non-VA disparities in joint replacement surgery that we classified as second-generation studies. Of these, four were also included in the review by Kane and colleagues.69-72 These studies focused on a handful of topics including severity of OA, knowledge of joint replacement, perceived benefits and fear of surgery, consideration of surgery in the past, impact of socioeconomic factors, patient attitudes and beliefs, willingness-to-pay, referral to a surgeon, and receipt of surgery at a low volume hospital or by a low volume surgeon. An individual study could report on one or more of these topics.

Eight studies looked at knowledge, perceived benefits, or fear of joint replacement surgery.57, 69-75 Three studies assessing knowledge of or familiarity with joint replacement surgery found that, in general, African-Americans had less knowledge than whites or were less likely to have known someone who had undergone this surgery.69, 72, 75 African-Americans had greater fear before and after hip or knee arthroplasty than whites.74 Another study found that health beliefs differed by race/ethnicity. Trust was a critical issue for Hispanic patients, while overall economic issues were less important.74

In race-based focus groups, Whites, Hispanics, and African-Americans differed in their explanations of causal factors for OA, the change in lifestyle from OA, their trust of and skepticism about the physician, and payment for TKR.76 African-Americans reported low expectations that TKR would improve their joint pain or health,70 but there was no comparison race/ethnicity group in this particular study. Expectations about joint replacement surgery were lower among African-American men relative to white women, even after adjustment of socioeconomic factors.57 Whites were more likely to consider TKR surgery beneficial.69 One study using race concordant facilitators for focus groups suggested that differences in health beliefs and attitudes about surgery were primarily based on personal experiences; contrary to the other studies, the study concluded that African-Americans did not have more concerns/fears or worse expectations than whites.73 Another study's qualitative interviews with black participants reinforce the findings that blacks had a preference for natural remedies, negative expectations of surgery, beliefs about God's control, a preference for continuing in their current state, poor relationships with specialists, and fear of surgery or death.71 One of the above studies did not find differences in self-treatment for joint pain.75

Four studies assessed aspects of pre-operative and/or post-operative function across different racial groups.77-80 Two studies, one conducted at New York University hospital and another at University of Pennsylvania hospital, found that African Americans had worse pre-operative knee function compared with whites, and longer delays to presentation for surgery. African American women had worse post-operative function, but the incremental gain with joint replacement surgery was equivalent to whites. Both studies support the hypothesis that African American patients present for TKR in a more advanced state than whites, but that improvement in function is approximately equivalent.

A third study examined the variation in family structure and social support between various racial groups after an individual had undergone hip fracture surgery or lower extremity joint replacement. The study found that whites and blacks were statistically significantly more likely to be responsible for their own care and discharged home alone than were Hispanics or Asians.79 These differences in family structure and social support appear to be related to outcome disparities, with Hispanic males being the least likely to report hospital readmission at follow-up. Similarly, the last study found that blacks and Hispanics were more likely to be discharged to home following hip replacement, with Hispanics showing a statistically significant difference.80 Men also had higher odds of being discharged to home. However, mean functional status change did not predict discharge disposition, suggesting that ethnic and gender disparities exist in THR care outcomes.

Three studies using administrative data (California State and New York City) found race/ethnic disparities for receipt of joint replacement surgery by a low volume hospital or low volume surgeon.81, 82 Liu82 found that African-Americans, Hispanics and Asians were more likely to receive TKR in low volume hospitals, controlling for socioeconomic factors, comorbidities and distance to hospital. SooHoo83 also found that minorities as compared to white patients were more likely to undergo THR in low volume hospitals. Using New York City data, Epstein found that African-Americans, Hispanics, and Asians were more likely to receive total hip replacement in either a low volume hospital or by a low volume surgeon, also controlling for socioeconomic factors and distance to hospital.81 These studies may support the hypothesis that “geography is destiny,” meaning that where patients seek care largely influences the kinds and amount of care they receive.

Willingness-to-pay methodology was used in two studies by the same author group (both included the same subset of patients for the random dialing component). They found that African-Americans had a lower willingness-to-pay for TKR than whites,84, 85 but differences were not significant in one study for Hispanics after adjusting for confounders.85

One study found that African-Americans patients were less likely to have seen an orthopedic surgeon for hip/knee surgery.75 Physicians were more likely to discuss TKR with minorities (African-Americans and Hispanics), but whites were more likely to consider having surgery.69 Ethnic differences remained after controlling for disease severity. African-Americans patients, especially women, had longer delays to getting TKR surgery.77

An old study (data from 1970s and 1980s) documents lower use of TKR among blacks compared with whites, even in the Medicaid-eligible or Medicare population, questioning whether economic factors alone explain the differences.11 Another more recent study using data from the Health and Retirement Survey from 1998-2004 also found that relative poverty or access to care did not explain disparities between blacks and whites in receipt of joint replacement.62

Overall these studies are of moderate quality, and the results across studies and procedures are relatively consistent. We found few studies on Hispanics and Asians, and as such the evidence is of low quality for them.

### Summary of Findings

Evidence in non-VA settings suggests that minority patients (African Americans being the most studied) may have less knowledge about joint replacement surgery, perceive fewer health benefits, and have greater fear about the surgery, similar to findings within VA. These patients may be less likely to be referred to a surgeon and are less likely to consider surgery. When they do present for surgery, African Americans have more advanced disease. Disease severity, socioeconomic factors, or degree of comorbidities do not appear to account for all of these differences. Minority patients may be less likely to be treated in high volume centers or by high volume providers, which is a system-level factor that has not been studied within VA.

## KEY QUESTION #3 What is the evidence regarding VA or non-VA interventions to reduce disparities in joint replacement surgery?

We identified only one study of an intervention designed to reduce joint disparities in VA.44 The authors assessed a decision aid that attempted to improve patient knowledge and expectations. The decision aid was a 45-minute videotape created by the Foundation for Informed Medical Decision Making about the treatment options for knee osteoarthritis, including total joint replacement. One hundred and two veterans from the Greater Los Angeles VA Healthcare System were recruited via flyers in VA clinics and waiting areas. Eligible subjects had to have moderate to severe osteoarthritis (as defined by the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) of greater than 39) and have no significant medical comorbidities. Sixty-four subjects ended up watching the video, attending a focus group, and completing both pre- and post- video surveys about expectations regarding post-operative total knee replacement pain and function.

Compared with Caucasians, African Americans had worse pre-video expectations of pain and function following total knee replacement. After watching the video, expectations were unchanged for Caucasian veterans. However, African American veterans had statistically significant improvements in their expectations for pain and function post-operatively (see Table 3 below). The post-video expectations were therefore essentially the same for Caucasians and for African American veterans. The authors conclude that baseline disparities in expectations can be improved.

Table 3 Baseline and post-intervention total knee replacement expectations (n=64)

Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) scale 0-100, where higher scores reflect poorer expectations.

### Summary of Findings

There has been only one published VA study of an intervention to improve disparities. It focused on expectations and examined only total knee replacement. Other potential causes of disparities have not been the subjects of interventions, and no study has yet assessed changes in the actual delivery of joint replacement surgery.

The quality of evidence for this key question is very low, due to sparseness of data; thus any estimate of effect is uncertain.