# REFERENCES

1 DuBard CA, et al. Racial/ethnic differences in quality of care for North Carolina Medicaid recipients. N C Med J. 2009;70(2):96-101. [pmid: 19489363].
2 Lillie-Blanton M, et al. Race, ethnicity, and the health care system: public perceptions and experiences. Med Care Res Rev. 1. 2000;57:218-35. [pmid: 11092164].
3 Consensus development conference statement: total knee replacement. 2003. National Institute of Health.
4 Kane RL, et al. Total knee replacement. Evidence Report/Technology Assessment No. 86 (Prepared by the Minnesota Evidence-based Practice Center, Minneapolis, MN), AHRQ Publication. 2003. Agency for Healthcare Research and Quality. Rockville, MD. No. 04-E006-2.
5 NIH. consensus conference: total hip replacement. NIH consensus development panel on total hip replacement. JAMA. 1995;273:1950-1956. [pmid: 7783307].
6 Hochberg MC, et al. Guidelines for the medical management of osteoarthritis. Part II. Osteoarthritis of the knee. American College of Rheumatology. Arthritis Rheum. 1995;38(11):1541-6. [pmid: 7488273].
7 Dieppe P, et al. Knee replacement surgery for osteoarthritis: effectiveness, practice variations, indications and possible determinants of utilization. Rheumatology (Oxford). 1999;38(1):73-83. [pmid: 10334686].
8 Escarce JJ, et al. Racial differences in the elderly's use of medical procedures and diagnostic tests. Am J Public Health. 1993;83(7):948-54. [pmid: 8328615].
9 Baron JA, et al. Total hip arthroplasty: use and select complications in the US Medicare population. Am J Public Health. 1996;86(1):70-2. [pmid: 8561246].
10 Sharkness CM, et al. Prevalence of artificial hip implants and use of health services by recipients. Public Health Rep. 1993;108(1):70-5. [pmid: 8434101].
11 Wilson MG, May DS, Kelly JJ. Racial differences in the use of total knee arthroplasty for osteoarthritis among older Americans. Ethn Dis. 1994;4(1):57-67. [pmid: 7742733].
12 Hoaglund FT, Oishi CS, Gialamas GG. Extreme variations in racial rates of total hip arthroplasty for primary coxarthrosis: a population-based study in San Francisco. Ann Rheum Dis. 1995;54(2):107-10. [pmid: 7702396].
13 Katz JN, et al. Can comorbidity be measured by questionnaire rather than medical record review?. Med Care. 1996;34(1):73-84. [pmid: 8551813].
14 Giacomini MK. Gender and ethnic differences in hospital-based procedure utilization in California. Arch Intern Med. 1996;156(11):1217-24. [pmid: 8639016].
15 Escalante A, et al. Recipients of hip replacement for arthritis are less likely to be Hispanic, independent of access to health care and socioeconomic status. Arthritis Rheum. 2000;43(2):390-9. [pmid: 10693880].
16 Mehrotra C, et al. Trends in total knee replacement surgeries and implications for public health, 1990-2000. Public Health Rep. 2005;120(3):278-82. [pmid: 16134568].
17 Ibrahim SA. Racial variations in the utilization of knee and hip joint replacement: an introduction and review of the most recent literature. Curr Orthop Pract. 21(2):126-131. [pmid: 21132110].
18 Morgan RC Jr, Slover J. Breakout session: Ethnic and racial disparities in joint arthroplasty. Clin Orthop Relat Res. 469(7):1886-90. [pmid: 21503786].
19 Singh JA. Epidemiology of knee and hip arthroplasty: a systematic review. Open Orthop J. 5:80-5. [pmid: 21584277].
20 Kane RL, et al. Disparities in total knee replacements: a review. Arthritis Rheum. 2007;57(4):562-7. [pmid: 17471555].
21 Wennberg JE. The geography of health care in the United States, The Dartmouth atlas of health care. Wennberg JE, McAndrew CM, editors. American Publishing, Inc. Chicago. 1996:11-35.
22 Wennberg JE. Dealing with medical practice variations: a proposal for action. Health Aff (Millwood). 1984;3(2):6-32. [pmid: 6432667].
23 Jadad AR, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
24 Wells G, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000. Available from: http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
25 Kilbourne AM, et al. Advancing health disparities research within the health care system: a conceptual framework. Am J Public Health. 2006;96(12):2113-21. [pmid: 17077411].
26 Hausmann LR, et al. The Effect of Patient Race on Total Joint Replacement Recommendations and Utilization in the Orthopedic Setting. J Gen Intern Med. 2010.
27 Jones A, et al. Racial disparity in knee arthroplasty utilization in the veterans health administration. Arthritis Rheum. 2005;53(6):979-81. [pmid: 16342110].
28 Ibrahim SA, et al. Racial/ethnic differences in surgical outcomes in veterans following knee or hip arthroplasty. Arthritis Rheum. 2005;52(10):3143-51. [pmid: 16200594].
29 Hausmann LR, et al. Orthopedic communication about osteoarthritis treatment: does patient race matter?. Arthritis Care Res. 2011;63(5):635-642.
30 Ang DC, James G, Stump TE. Clinical appropriateness and not race predicted referral for joint arthroplasty. Arthritis Rheum. 2009;61(12):1677-85. [pmid: 19950319].
31 Ang DC, et al. African Americans and Whites are equally appropriate to be considered for total joint arthroplasty. J Rheumatol. 2009;36(9):1971-6. [pmid: 19605675].
32 Ang DC, Monahan PO, Cronan TA. Understanding ethnic disparities in the use of total joint arthroplasty: application of the health belief model. Arthritis Rheum. 2008;59(1):102-8. [pmid: 18163395].
33 Jones AC, et al. Investigating racial differences in coping with chronic osteoarthritis pain. J Cross Cult Gerontol. 2008;23(4):339-47. [pmid: 18561011].
34 Groeneveld PW, et al. Racial differences in expectations of joint replacement surgery outcomes. Arthritis Rheum. 2008;59(5):730-7. [pmid: 18438917].
35 Weng HH, Fitzgerald J. Current issues in joint replacement surgery. Curr Opin Rheumatol. 2006;18(2):163-9. [pmid: 16462522].
36 Lopez JP, et al. Patient perceptions of access to care and referrals to specialists: a comparison of African-American and white older patients with knee and hip osteoarthritis. J Natl Med Assoc. 2005;97(5):667-73. [pmid: 15926643].
37 Ang DC, et al. Is there a difference in the perception of symptoms between african americans and whites with osteoarthritis?. J Rheumatol. 2003;30(6):1305-10. [pmid: 12784407].
38 Ibrahim SA, et al. Older patients' perceptions of quality of chronic knee or hip pain: differences by ethnicity and relationship to clinical variables. J Gerontol A Biol Sci Med Sci. 2003;58(5):M472-7. [pmid: 12730259].
39 Ibrahim SA, et al. Differences in expectations of outcome mediate African American/white patient differences in “willingness” to consider joint replacement. Arthritis Rheum. 2002;46(9):2429-35. [pmid: 12355491].
40 Ang DC, et al. Ethnic differences in the perception of prayer and consideration of joint arthroplasty. Med Care. 2002;40(6):471-6. [pmid: 12021673].
41 Ibrahim SA, et al. Self-assessed global quality of life: a comparison between African-American and white older patients with arthritis. J Clin Epidemiol. 2002;55(5):512-7. [pmid: 12007555].
42 Ibrahim SA, et al. Understanding ethnic differences in the utilization of joint replacement for osteoarthritis: the role of patient-level factors. Med Care. 2002;40(1 Suppl):I44-51. [pmid: 11789631].
43 Ibrahim SA, et al. Variation in perceptions of treatment and self-care practices in elderly with osteoarthritis: a comparison between African American and white patients. Arthritis Rheum. 2001;45(4):340-5. [pmid: 11501721].
44 Weng HH, et al. Development of a decision aid to address racial disparities in utilization of knee replacement surgery. Arthritis Rheum. 2007;57(4):568-75. [pmid: 17471558].
45 Borrero S, et al. Brief report: Gender and total knee/hip arthroplasty utilization rate in the VA system. J Gen Intern Med. 3. 2006:S54-7.
46 Hawker GA, et al. Differences between men and women in the rate of use of hip and knee arthroplasty. N Engl J Med. 2000;342(14):1016-22. [pmid: 10749964].
47 Skinner J, et al. Racial, ethnic, and geographic disparities in rates of knee arthroplasty among Medicare patients. N Engl J Med. 2003;349(14):1350-9. [pmid: 14523144].
48 Escalante A, et al. Disparity in total hip replacement affecting Hispanic Medicare beneficiaries. Med Care. 2002;40(6):451-60. [pmid: 12021671].
49 Katz BP, et al. Demographic variation in the rate of knee replacement: a multi-year analysis. Health Serv Res. 1996;31(2):125-40. [pmid: 8675435].
50 McBean AM, Gornick M. Differences by race in the rates of procedures performed in hospitals for Medicare beneficiaries. Health Care Financ Rev. 1994;15(4):77-90. [pmid: 10172157].
51 Racial disparities in total knee replacement among Medicare enrollees--United States, 2000-2006. MMWR Morb Mortal Wkly Rep. 2009;58(6):133-8. [pmid: 19229164].
52 Jha AK, et al. Racial trends in the use of major procedures among the elderly. N Engl J Med. 2005;353(7):683-91. [pmid: 16107621].
53 Skinner J, Zhou W, Weinstein J. The influence of income and race on total knee arthroplasty in the United States. J Bone Joint Surg Am. 2006;88(10):2159-66. [pmid: 17015592].
54 Hawkins K, et al. Disparities in Major Joint Replacement Surgery among Adults with Medicare Supplement Insurance. Popul Health Manag.
55 Jain NB, et al. Trends in epidemiology of knee arthroplasty in the United States, 1990-2000. Arthritis Rheum. 2005;52(12):3928-33. [pmid: 16320340].
56 Bang H, et al. Total hip and total knee arthroplasties: trends and disparities revisited. Am J Orthop (Belle Mead NJ). 39(9):E95-102. [pmid: 21290031].
57 Hanchate AD, et al. Exploring the determinants of racial and ethnic disparities in total knee arthroplasty: health insurance, income, and assets. Med Care. 2008;46(5):481-8. [pmid: 18438196].
58 Olson JC, Foland J. Tracking racial and ethnic disparities of knee replacement rates in Connecticut. Conn Med. 2005;69(4):211-5. [pmid: 15926636].
59 Basu J, Mobley LR. Trends in racial disparities among the elderly for selected procedures. Med Care Res Rev. 2008;65(5):617-37. [pmid: 18490701].
60 Oishi CS, et al. Total hip replacement rates are higher among Caucasians than Asians in Hawaii. Clin Orthop Relat Res. 1998;(353):166-74. [pmid: 9728171].
61 Francis ML, et al. Joint replacement surgeries among medicare beneficiaries in rural compared with urban areas. Arthritis Rheum. 2009;60(12):3554-62. [pmid: 19950278].
62 Steel N, et al. Racial disparities in receipt of hip and knee joint replacements are not explained by need: the Health and Retirement Study 1998-2004. J Gerontol A Biol Sci Med Sci. 2008;63(6):629-34. [pmid: 18559639].
63 Unequal Treament: Confronting Racial and Ethnic Disparities in Health Care, Institute of Medicine. Smedley BD, Stith AY, Nelson AR, editors. 2002. Washington, DC. National Academy Press.
64 King RK, et al. A plan for action: key perspectives from the racial/ethnic disparities strategy forum. Milbank Q. 2008;86(2):241-72. [pmid: 18522613].
65 Klonoff EA. Disparities in the provision of medical care: an outcome in search of an explanation. J Behav Med. 2009;32(1):48-63. [pmid: 19127421].
66 Saha S, et al. Racial and ethnic disparities in the VA health care system: a systematic review. J Gen Intern Med. 2008;23(5):654-71. [pmid: 18301951].
67 Anderson KO, Green CR, Payne R. Racial and ethnic disparities in pain: causes and consequences of unequal care. J Pain. 2009;10(12):1187-204. [pmid: 19944378].
68 Allen KD. Racial and ethnic disparities in osteoarthritis phenotypes. Curr Opin Rheumatol. 22(5):528-32. [pmid: 20473172].
69 Suarez-Almazor ME, et al. Ethnic variation in knee replacement: patient preferences or uninformed disparity?. Arch Intern Med. 2005;165(10):1117-24. [pmid: 15911724].
70 Figaro MK, Williams-Russo P, Allegrante JP. Expectation and outlook: the impact of patient preference on arthritis care among African Americans. J Ambul Care Manage. 2005;28(1):41-8. [pmid: 15682960].
71 Figaro MK, Russo PW, Allegrante JP. Preferences for arthritis care among urban African Americans: “I don't want to be cut”. Health Psychol. 2004;23(3):324-9. [pmid: 15099175].
72 Chang HJ, et al. Concerns of patients actively contemplating total knee replacement: differences by race and gender. Arthritis Rheum. 2004;51(1):117-23. [pmid: 14872464].
73 Suarez-Almazor ME, et al. A qualitative analysis of decision-making for total knee replacement in patients with osteoarthritis. J Clin Rheumatol. 2010;16(4):158-63. [pmid: 20414128].
74 Lavernia CJ, Alcerro JC, Rossi MD. Fear in arthroplasty surgery: the role of race. Clin Orthop Relat Res. 2010;468(2):547-54. [pmid: 19763716].
75 Blake VA, et al. Racial differences in social network experience and perceptions of benefit of arthritis treatments among New York City Medicare beneficiaries with self-reported hip and knee pain. Arthritis Rheum. 2002;47(4):366-71. [pmid: 12209481].
76 Kroll TL, et al. “Keep on truckin'” or “It's got you in this little vacuum”: race-based perceptions in decision-making for total knee arthroplasty. J Rheumatol. 2007;34(5):1069-75. [pmid: 17407213].
77 Kamath AF, et al. Ethnic and Gender Differences in the Functional Disparities after Primary Total Knee Arthroplasty. Clin Orthop Relat Res. 2010.
78 Slover JD, Walsh MG, Zuckerman JD. Sex and race characteristics in patients undergoing hip and knee arthroplasty in an urban setting. J Arthroplasty. 2010;25(4):576-80. [pmid: 19427753].
79 Ottenbacher KJ, et al. Disparity in health services and outcomes for persons with hip fracture and lower extremity joint replacement. Med Care. 2003;41(2):232-41. [pmid: 12555051].
80 Berges IM, et al. Gender and ethnic differences in rehabilitation outcomes after hip-replacement surgery. Am J Phys Med Rehabil. 2008;87(7):567-72. [pmid: 18574348].
81 Epstein AJ, Gray BH, Schlesinger M. Racial and ethnic differences in the use of high-volume hospitals and surgeons. Arch Surg. 2010;145(2):179-86. [pmid: 20157087].
82 Liu JH, et al. Disparities in the utilization of high-volume hospitals for complex surgery. JAMA. 2006;296(16):1973-80. [pmid: 17062860].
83 SooHoo NF, Farng E, Zingmond DS. Disparities in the utilization of high-volume hospitals for total hip replacement. J Natl Med Assoc. 103(1):31-5. [pmid: 21329244].
84 Byrne MM, et al. Racial/ethnic differences in preferences for total knee replacement surgery. J Clin Epidemiol. 2006;59(10):1078-86. [pmid: 16980148].
85 Byrne MM, O'Malley KJ, Suarez-Almazor ME. Ethnic differences in health preferences: analysis using willingness-to-pay. J Rheumatol. 2004;31(9):1811-8. [pmid: 15338505].