# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Tamara L. Martin, MD and the Center for Health Equity Research and Promotion, with input from a technical expert group that included Said Ibrahim and David Atkins.

The final key questions are:

Key Question #1 What is the evidence about the existence and magnitude of disparities in joint replacement surgery in VA? How does this compare to published studies from non-VA US populations?
Key Question #2 What is the evidence about the patient level, provider level, and system level factors that contribute to disparities in joint replacement surgery in VA? How does this compare to published studies from non-VA populations?
Key Question #3 What is the evidence regarding VA or non-VA interventions to reduce disparities in joint replacement surgery?

Evidence Synthesis Program systematic reviews are done according to a standard protocol, which is modeled on the protocol used by the Evidence-Based Practice Center program. A detailed individual protocol is not created for each separate topic.

## SEARCH STRATEGY

We searched PubMed for relevant literature from 1966 through July 2011, using standard search terms such as “disparities,” “variations,” “replacement,” and “arthroplasty” (see Appendix A for complete search strategy). We limited the search to peer-reviewed articles involving human subjects and published in the English language. We judged it unlikely for studies of US patients, either VA or non-VA, to be published in non-English language journals. Since our focus was US studies, we elected to forgo searching EMBASE. Also, since RCTs are not the study design to assess anything but third generation disparity questions, we elected to forgo searching the Cochrane Central Register of Controlled Trials (CENTRAL).

## STUDY SELECTION

Two reviewers assessed for relevance the abstracts of citations identified from literature searches. Full text articles of potentially relevant abstracts were retrieved for further review. Each article was reviewed using a standard screener form (see Appendix B). Inclusion criteria were: 1) reported on hip, knee (or both) total joint replacement; 2) reported on patients treated within the VA or who were treated in non-VA health care settings in the United States; and 3) reported results of either racial/ethnic or gender disparities. There were no inclusion or exclusion criteria for study design. We excluded studies of joint replacement surgery for other sites (such as shoulder). Additionally, we excluded studies if there were about gender differences in the technical approach to the procedure (e.g., use of gender-specific prostheses).

## DATA ABSTRACTION

We abstracted the following data for each included study for the key questions: intervention(s), data source, study subjects, patient selection, years of data collection, study design, outcome measure(s), categorization of race(s), determination of race, assessment of receipt of procedure, assessment of disparity outcome, population sample size, mean/median patient age, response rate, subject follow-up, and covariates for result adjustment (Appendix C).

## QUALITY ASSESSMENT

We assessed individual randomized studies using the criteria of Jadad.23 We assessed non-randomized studies using items taken or derived from the Newcastle Ottawa Scale, involving representativeness of the sample and how key variables were assessed24 (see Appendix D for adapted variables).

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question or clinical topic, and drew conclusions based on qualitative synthesis of the findings. We used the conceptual framework of Kilbourne and colleagues (see Figure 2) to organize the reasons for disparities assessed in the second-generation studies.25

Figure 2 Kilbourne et al. model:25 Understanding the origins of health and health care disparities from a health services research perspective: key potential determinants of health disparities within the health care system, including individual, provider, and health care system factors

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group, which classified the evidence across outcomes according to the following criteria:

- High = Further research is very unlikely to change our confidence about the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

The ESP SharePoint site {http://vaww.infoshare.va.gov/sites/hsrd/esp/default.aspx} contains reference articles that describe guidelines for the GRADE quality assessment system.

## PEER REVIEW

A draft version of this report was reviewed by seven technical experts as well as by VA clinical leadership. Their comments and our responses are presented in Appendix E.