# INTRODUCTION

## BACKGROUND

The leading cause of disability in the United States is osteoarthritis.1, 2 There is no known cure. Consequently, osteoarthritis is managed with a variety of treatments to reduce disability, improve function, and alleviate symptoms. The most effective surgical option for moderate to severe osteoarthritis in the knee or hip is total joint replacement (TJR).3, 4 TJR is often considered appropriate in cases where other non-surgical treatments have not brought adequate relief.2, 5-7

Although TJR is highly successful at treating advanced hip or knee osteoarthritis, there is a large body of evidence suggesting that disparities exist in TJR utilization in non-VA settings.8-19 Although subgroups of patients may utilize services differently depending on clinical needs, Kane et al. explain that “disparity in healthcare implies unequality, unlikeness, or unfair disproportion,”20 as opposed to extensive accepted variation in practice.21, 22 Measuring disparities usually means comparing rates of utilization of care, since measuring access to care directly can be difficult.20 But if only utilization is measured, and need for care is not taken into account, disparities might not be fully characterized. “Need for care” data are not easily captured, making this concept almost as hard to measure as access to care. Utilization data are so often relied upon when discussing disparities because of this difficulty of measuring access to care or need for care.

In order to remedy disparities, they must first be documented and their causes better understood. Disparities in TJR utilizations have been well documented outside VA. The purpose of this report is to compare what is known about disparities in TJR in non-VA settings to disparities in TJR in the VA context.

Our conceptual framework identifies three “generations” of studies of disparities, based on whether the studies are documenting disparities, examining their underlying reasons, or assessing interventions to address them (see Figure 1).

Figure 1 Conceptual Framework