# EVIDENCE TABLES

Key Question 1/ Generation 1 Evidence Table

Author; Date | Data Dates^*^ | Study Type; Sample Selection; Response Rate/ Follow Up | Total pop; VA pop^*^ | Data Source | Gender, Race^**^/How determined | Joint Discussed^***^ | Outcomes | Results
VA Studies
Hausmann; 2010^26^ | 2005-2008 | Cohort/ Case-control; Unclear; Not specified | 457; 457 | VA, multi-institution | W/ Self-Reported | TKR, THR | recommendation for procedure; receipt of procedure | Lower odds of receiving a TJR recommendation for B than W of similar age and disease severity (OR 0.46, [95% CI 0.26–0.83]; P=0.01). Difference was not significant adjusting for patient preference for TJR (OR 0.69, [95% CI 0.36–1.31], P=0.25).TJR less likely for B than W of similar age and disease severity (OR 0.41 [95% CI 0.16–1.0], P=0.06); difference reduced adjusting for recommendation for procedure at the index visit (OR 0.57 [95% CI 0.21–1.54], P=0.27).
Borrero; 2006^45^ | 1999 | Cross-sectional; Pop based; N/A | 329,461; 329,461 | VA National | Women/ Admin | TKR, THR | Adjusted odds of getting TJR | Among patients with OA, men and women in the VA were equally likely to undergo TKR (153 [1.6%] women and 4,638 [1.5%]) men and THR (73 [.8%] women and 2147 [.7%] men). Receipt of surgery within 2 years for women with OA versus men was not significant (TKR: OR 0.96 [95% CI 0.82 to 1.13]) and (THR: OR 0.99 [95% CI 0.79 to 1.26]).
Jones; 2005^27^ | 1999 | Cohort/ Case-control; Pop based; Not specified | 260856; 260856 | VA National | W, B/ Admin. data | TKR | receipt of procedure | B were less likely than W to have received TKA within 2 years (OR 0.72, [95% CI 0.65–0.80] in OA cohort and OR 0.72, [95%CI 0.63–0.81] in specialty clinic subcohort.
Non-VA Studies
Hawkins; 2011^54^ | 2006-2007 | Cross-sectional; Pop-based; N/A | 2.9 million; 0 | Medigap | % non-white by zip code/ Admin | Hip or knee replacement | receipt of procedure | Patients living in high-minority areas were 20% less likely to undergo a hip or knee replacement as low minority areas.
Bang; 2010^56^ | 1996-2005 | Cross-sectional; Pop-based; N/A | 8000000 | NIS | W, B, H, A/ Admin | TKR, THR | receipt of procedure | Non-whites had lower odds of THA and TKA compared with whites. Minorities were 23% to 64% less likely to undergo arthroplasties. Racial disparities were larger than income disparities and not confined to elderly or low-income.
Francis; 2009^61^ | 2005 | Cross-sectional; Pop-based; N/A | 46000000; 0 | Medicare, NIS | W, B, H, A/ Admin. data | TKR, THR | receipt of procedure | Compared with urban beneficiaries, rural were more likely to have TJR (OR 1.27 [95% CI 1.26–1.28]). Adjusting for age, sex, race/ethnicity, income, poverty ratio, and state, rural beneficiaries were still 14% more likely to have TJR (OR 1.14 [95% CI 1.13–1.16]).
2009^51^ | 2000/2006 | Cross-sectional; Pop-based; N/A | 26000000; N/A | Medicare | W, B/ Admin. data | TKR | receipt of procedure | From 2000 to 2006, TKR rate in the US increased 58%, from 5.5 to 8.7 per 1,000, with similar increases among W (61%) and B (56%). Rate of TKR for B was 37% lower than W in 2000 (3.6 versus 5.7 per 1,000) and 39% lower in 2006 (5.6 versus 9.2 per 1,000).
Basu; 2008^59^ | 1997-2001 | Cross-sectional; Pop-based; N/A | 71418; NR | National, HCUP | W, B, H/ Admin. data | THR | receipt of procedure | No difference in the likelihood of THR between B, W and H for 1997 or 2000, after adjusting for income, urban/rural, distance from hospital, and social isolation, but not severity of arthritis.
Steel; 2008^62^ | 1998, 2000, 2002 | Cohort/ Case-control; Pop-based; Not specified | 14807; NR | Health and retirement study, national | W, B/Self-reported | TKR, THR | need for surgery; receipt of procedure | Lower receipt of TJR in B (vs W: OR 0.47; CI 0.26–0.83) or less educated (0.65; 0.44–0.96). Differences not explained by employment, access, family responsibilities, disability, living alone, comorbidity, or excluding younger than Medicare.
Hanchate; 2008^57^ | 1994-2004 | Cohort/ Case-control; Pop-based; Not specified | 18439; NR | National | W, B, H/ Self-reported | TKR | receipt of procedure | B men (relative to W women) were less likely (OR 0.46 (0.28–0.78), [P < 0.05]) to receive TKA. Adjusting for economic factors, racial/ethnicity, TKA rates differences for women disappeared, while remaining large for B men (OR 0.56 [0.33–0.95]).
Skinner; 2006^53^ | 2000 (Medicare) | Cross-sectional; Pop-based; N/A | 27494659; NR | NHANES, national Medicare | W, B, H, A/ Admin. data | TKR | receipt of procedure; Prevalence of OA | Relative to W men, B men were less likely to undergo TKA (OR 0.36 [95% CI 0.34 to 0.38); as were H men (OR 0.67 [0.62 to 0.73]; Asian men (OR 0.28 [0.24 to 0.32]; and Asian women (OR 0.45 [0.41 to 0.49]. W women were more likely (OR 1.34 [1.33 to 1.36]). [No income gradient for clinical and radiographic measures of arthritis, except a negative association of income and pain on passive motion (P<.05).]
Jain; 2005^55^ | 1990-2000 | Cross-sectional; Pop-based; N/A | 443008; NR | NIS, national | W, B, H/ Admin. data | TKR | receipt of procedure | In 1998-2000 as compared to 1990-1993, B and Hispanic patients were more likely to undergo TKA (OR 1.6 [95% CI 1.5–1.6] and OR 2.7, [95% CI 2.5–2.9], respectively). However, W patients accounted for 87.5% and 93.0% of TKAs, in the 2 time periods.
Jha; 2005^52^ | 1992-2001 | Cross-sectional; Pop-based; N/A | 29000000; NR | Medicare | Non-B/ Admin. data | THR | receipt of procedure | Rates of TKR and THR among the Medicare fee for service population were compared from 1992 to 2001. Women had higher age-adjusted rates of procedure use than men, and nonblacks had higher rates than blacks. In 2001, nonblack men had a rate of 5.05/1000 population for TKR, compared to 1.85 for black men. Among women, rates of TKR per 1000 population were 6.6 among nonblacks and 5.1 among blacks.
Mehrotra; 2005^16^ | 1990-2000 | Cross-sectional; Pop-based; N/A | 67,475; NR | Regional (Wisconsin Hospital Discharges) | Gender/ Admin. data | TKR | receipt of procedure | In both 1990 and 2000, women had higher rates of TKR. Rates of TKR per 100,000 in 1990 were 30 for women compared to 23 in men, and in 2000 were 46 in women compared to 35 in men.
Olson; 2005^58^ | 1993-2001 | Cross-sectional; Pop-based; N/A | Many; NR | Regional | W, B, H/ Admin. data | TKR | receipt of procedure | Connecticut hospital data (1996-1998) found that age adjusted rates per 100K discharges for TKR was highest for black women (115.8, 95% CI 103.9-127.7) and lowest for black men (44, 34.9-68.9) and Hispanic men (16.9, 10.1-23.8) and women (47.5, 37.8-57.2). White women had rates of 84.9 (82.4-87.4) and men 66.5 (63.9 -68.9).
Skinner; 2003^47^ | 1998-2000 | Cross-sectional; Pop-based; N/A | 403251; 0 | National, Medicare | W, B, H/ Admin. data | TKR | receipt of procedure | Rate of TKA was higher for W women (5.97 procedures per 1000) than for H women (5.37 per 1000) and B women (4.84 per 1000). Rate for W men (4.82 procedures per 1000) was higher than H men (3.46 per 1000) and more than double that for B men (1.84 per 1000). The rates were lower for B men in nearly every region of the country (P<0.05). [For H population and for B women, racial/ethnic disparities were due in part to geographic differences rather than to differences in the rates for racial and ethnic groups within geographic areas. Residential segregation and low income levels contributed to disparities.]
Escalante; 2002^48^ | 95-96 | Cross-sectional; Pop-based; N/A | 19311; 0 | Medicare in NM, IL, TX, AZ | W, B, H, A/ Two or more sources | THR | receipt of procedure | 1% THR recipients and 3.3% controls were H (P<.001). Odds of THR decreased as probability of H ethnicity increased (OR 1.00 non-H surnames to OR 0.36 H surnames (95% CI, 0.31, 0.43). Poverty did not modify the low odds of THR among H (OR, 0.25 Medicaid-eligible Hispanic persons; 95% CI, 0.19, 0.33; and OR, 0.30 Hispanic persons not Medicaid eligible; 95% CI, 0.24, 0.38).
Oishi; 1998^60^ | 85-89 | Cross-sectional; NR; N/A | 754; 0 | Regional | W, A/ Medical record review | THR | receipt of procedure | THR for W was three to 25 times greater than that of Japanese, Chinese, Filipino, and Hawaiians. Risk of THR for W women was 4.4%, compared with 1.1% for Japanese women and 1.7% for Chinese women. For white men, the incidence rate is 3.6%, which is 4.5 to nine times greater than the rate for other ethnic groups. Some between region differences were noted (Hawaii versus San Francisco).
Giacomini; 1996^14^ | 1989-1990 | Cross-sectional; Pop-based; N/A | 6586; NR | OSHPD, regional | W, B, H, A/ NR | THR | receipt of procedure | Asians had higher odds of THR (OR 2.13 [95% CI 1.3-3.45]) than W. W had higher, but non-significant, odds of THR than H (OR 1.32 [.87-1.96]) and than B (OR 1.56 [.97-2.50]).
Katz; 1996^49^ | 85-90 | Cross-sectional; Pop-based; N/A | 414079; 0 | Medicare, national | W, B/ Two or more sources | TKR | receipt of procedure | Odds of W receiving TKR were 1.5 times greater than for B. Adjusting for demographic factors, regional variation remained. TKR were over two and one-half times more likely for B women than for men (OR 1.66); the difference was only 24 percent for W women versus W men (OR = 1.24). Procedures were performed on W men much more often than on B, (OR 2.50). Difference between W and B women was much smaller (OR = 1.16).
Hoaglund; 1995^12^ | 84-88 | Cross-sectional; Pop-based; N/A | 1589; 0 | San Francisco | W, B, H, A/ Medical record review | THR | receipt of procedure | The greatest annual rate of THR occurred in W women (97 per 100 000), followed by W men, B women, B men, H women, and H men. Smallest numbers were found in Asians, rate was 10% of W. Age standardized THR rates for primary coxarthrosis per 100 000 were greatest among W (43.0) and least among Asians (1.3 for Chinese). Mean age undergoing THR for primary coxarthrosis was 70 years for W and a decade younger in other groups.
McBean; 1994^50^ | 86-92 | Cross-sectional; Pop-based; N/A | a lot; 0 | Medicare, national | W, B/ Admin. data | TKR, THR | receipt of procedure | TKR increased from 1986 and 1992, 98% among white beneficiaries and 121 percent among blacks. In 1992, the rate in blacks was 64% as great as for whites.
Wilson; 1994^11^ | 1980-1988 | Cross-sectional; Pop-based; N/A | over 3000; NR | NHANES, Medicare | W, B/ Admin. data | TKR | receipt of procedure; Rate of OA | B were less often treated with TKR than W (men: OR=3.16 [1.69-5.91]; women: OR=1.55 [1.00-2.41]) for age 65-69.
Escarce; 1993^8^ | 1986 | Cross-sectional; Pop based; N/A | 1204022; 0 | Medicare, national | W, B/ Admin. data | TKR, THR | receipt of procedure | W are two-fold more likely to undergo THR (RR 2.36 [1.92, 2.89]) or TKR (RR 2.02 [1.63, 2.49]) than blacks.

* No data denoted as NR or 999

** W= White; B= Black; H= Hispanic; A=Asian

*** TKR=Total Knee Replacement; THR=Total Hip Replacement

Key Question 2/ Generation 2 Evidence Table

Author; Date | Data Dates^*^ | Study Type; Sample Selection; Response Rate/ Follow Up | Total pop; VA pop^*^ | Data Source | Gender/ Race^**^/How determined | Joint Discussed^***^ | Outcomes | Results
Direct Comparison of VA and Non-VA Studies
Ang; 2009^30^ | 2003-2006 | Cohort/ Case-control; Convenience; 91.4% | 676; 388 | Single VA | W, B/Self-reported | TKR, THR | Appropriateness, benefits, barriers, OA severity, length of time to referral; outcome expectations of surgery, perceived risk | Clinical appropriateness (HR 1.95, [95% CI] 1.15–3.32; P <0.01) predicted referral to orthopedic surgery. Neither race (HR 1.30, 95% CI 0.94–2.05; P =0.1) nor health beliefs (HR 1.0, P = 0.5) were associated with referral status.
Ang; 2009^31^ | 2003-2006 | Cross-sectional; Convenience; 684/748 | 685; 388 | Single VA | W, B/Self-reported | TKR, THR | Appropriateness for procedure | There were no significant racial group differences (p = 0.3) in the proportions of those deemed clinically appropriate for TJR. Controlling for confounders (BMI, SES, education, county vs VA), race was not a predictor of clinical appropriateness for TJR (odds ratio 1.2, 95% CI [0.8–1.8], P =0.3).
Ang; 2008^32^ | 2003-2006 | Cross-sectional; Convenience | 691; 390 | Single VA | W, B/Self-reported | TJR | Benefits, barriers, OA severity, arthritis health belief scale | B perceived less benefit from TJR than W (58.1 vs 44.3%; P=0.0001; OR=.60 (.42-.86), P=.005; B more likely to perceive barriers 42.4 vs 30.8%; P=.002; OR=.60, [CI] .42- .86, P=.005); Race not predictive of perceived severity of OA OR=.97 (.62–1.53), P=.9
VA Studies
Hausmann 2011^29^ | 2005-2008 | Cohort/ Case-control; Unclear; Not Specified | 409; 409 | VA | W, B/Self-reported | TKR, THR | Patient-provider communication | Visits with B, compared with W, contained less discussion of biomedical topics (B=-9.14, 95% CI -16.73 - -1.54) and more rapport-building statements (B-7.84; 95% CI 1.85- 13.82. No racial differences in length of visit, overall amount of dialogue, patient activation/engagement statements, discussions of psychosocial issues, physician verbal dominance, displays of positive affect, or evidence of informed decision making.
Hausmann; 2010^26^ | 2005-2008 | Cohort/ Case-control; Unclear; Not specified | 457; 457 | VA | W, B/Self-reported | TKR, THR | recommendation for procedure; receipt of procedure | Lower odds of receiving a TJR recommendation for B than W of similar age and disease severity (OR 0.46, [95% CI 0.26–0.83]; P=0.01). Difference was not significant adjusting for patient preference for TJR (OR 0.69, [95% CI 0.36–1.31], P=0.25).TJR less likely for B than W of similar age and disease severity (OR 0.41 [95% CI 0.16–1.0], P=0.06); difference reduced adjusting for recommendation for procedure at the index visit (OR 0.57 [95% CI 0.21–1.54], P=0.27).
Jones; 2008^33^ | 999 | Cross-sectional; Convenience; N/A | 939; 939 | VA | W, B/Self-reported | TKR, THR | prayer for pain, coping strategies, self efficacy | B more likely to perceive prayer helpful (OR 3.38, 95% CI [2.35 to 4.86]) and use prayer (OR 2.28, 95% [1.66 to 3.13]) to treat osteoarthritis pain as compared to W. B more likely to use coping and praying (β=0.74, 95% CI [0.50 to 0.99]).
Groeneveld; 2008^34^ | 2004-2006 | Cross-sectional; Convenience; N/A | 909; 909 | VA | W, B/Self-reported | TKR, THR | outcome expectations of surgery | B knee OA patients have lower expectation score (scale 0-76) than W even with adjustment for disease severity, SES, social support, literacy and trust (difference -3.8 points [95% CI 1.2, 6.3], and 4.2 points (95% CI 0.4, 8.0) among hip patients.
Weng; 2007^44^ | 999 | Experimental; Convenience; Not specified | 64; 64 | VA | W, B/Self-reported | TKR | outcome expectations of surgery, willingness to consider surgery, knowledge of surgery, alternative treatment | B had lower (but not significant) expectations for TKR than W for pain (WOMAC score 41 versus 34; P=0.18) and physical function (WOMAC score 38 versus 30; P = 0.13). B were less likely to have heard of TKR (49% versus 72%; P =0.02) and less likely to know someone who had TKR (34% versus 53%; P =0.05) than W.
Ibrahim; 2005^28^ | 1996-2000 | Cohort/ Case-control; Pop-based; N/A | 18811; 18811 | NSQIP, VA | W, B, H/ Admin. data | TKR, THR | complications | Rates of non–infection and infection-related complications after TKA were higher among B compared with W (RR 1.50, [95% CI 1.08–2.10] and RR 1.42, [95% CI 1.06–1.90]). H had a higher risk of infection-related complications (RR 1.64, 95% CI 1.08–2.49) relative to W. Race/ethnicity was not associated with the risk of non–infection-related or infection-related complications for THR. 30-day mortality was 0.6% following TKA and 0.7% following THR, with no race/ ethnicity differences
Lopez; 2005^36^ | 1997-2000 | Cross-sectional; Convenience; 728/770 | 596; 596 | VA | W, B/Self-reported | TKR, THR | participant/ provider relationship, perception access to care, receipt of referral | B were less likely than W to report difficulty getting medical care (OR 0.54 [0.34-0.88]). B were less likely than W to perceive the patient-physician relationship as excellent (24.7% vs. 36.3%, P<0.0 1) and less likely to have confidence in their primary physician (75.7% vs. 82.6%, P=0.04). Difficulty accessing care outside VA was not different between groups (52.4% vs. 52.2%, P=0.95).
Ang; 2003^37^ | 999 | Cross-sectional; Convenience; 38 lost to follow up | 558; 558 | VA | W, B/Self-reported | TKR, THR | perception of symptoms | B and W were not different in mean scores for WOMAC pain and WOMAC function when stratified by joint space narrowing, osteophyte and Kellgren Lawrence grades. After controlling for important covariates, ethnicity was not a significant predictor of WOMAC pain and function.
Ibrahim; 2003^38^ | 999 | Cross-sectional; Convenience; Not specified | 300; 300 | VA | W, B/Self-reported | TKR, THR | Perception of pain | B and W patients describe the quality of their chronic knee and hip pain differently. Chronic pain quality descriptions correlate with western Ontario and McMaster Universities Arthritis Index Scores but not radiologic stage of disease. {factor analyses}
Ibrahim; 2002^39^ | 1997-2000 | Cross-sectional; Convenience; 738/776 | 596; 596 | VA | W, B/Self-reported | TKR, THR | willingness to consider surgery, outcome expectations of surgery, familiarity with surgery | B were less likely than W to be willing to consider surgery for severe arthritis (OR 0.53, [95% CI 0.30-0.96]. After adjustment for outcome expectations, the difference between races in willingness to consider was not significant (OR 0.86, [95% CI 0.45-1.63]).
Ang; 2002^40^ | 97-00 | Cross-sectional; Convenience; 95% | 596; 596 | VA | W, B/Self-reported | TKR, THR | Role of prayer in the management of arthritis, willingness to consider surgery | B less willing than W to consider surgery for severe hip or knee arthritis pain (OR .059, [95% CI 0.34-0.99]). B more likely than W to perceive prayer as helpful in managing their arthritis (OR 2.1; [95% CI, 1.19, 3.72]).
Ibrahim; 2002^41^ | 97-00 | Cross-sectional; Convenience; 738/776 | 596; 596 | VA | W, B/Self-reported | TKR, THR | QOL | For patients with chronic joint disease, B less likely than W to rate quality of life as excellent or very good. Difference persisted after adjusting for demographic, clinical, and psychosocial covariates, and severity of osteoarthritis (B=-0.121, P=.004).
Ibrahim; 2002^42^ | 97-00 | Cross-sectional; Convenience; 738/776 | 596; 596 | VA | W, B/Self-reported | TKR, THR | outcome expectations of surgery, knowledge of joint replacement | B were less likely than W to have family/friends that had TJR (OR 0.39 [.26-.61]) or a good understanding of TRJ (OR 0.62 [.42-.92]). B more likely to expect longer hospital course (OR 4.09 [2.57-6.54]), moderate to extreme pain (OR 2.61 [1.74-3.89]), moderate to extreme difficulty walking after joint replacement (OR 2.76 [1.83-4.16]).
Ibrahim; 2001^43^ | 97-00 | Cross-sectional; Convenience; 738/776 | 593; 593 | VA | W, B/Self-reported | joint replacement | efficacy arthritis treatment | B were more likely than W to perceive TJR as efficacious (OR .52 [.28-.98]) and more likely to rely on self-care measures for their arthritis (OTC meds: OR 1.76 [1.14-2.72]); friend/family advice: OR 2.11 [1.44-3.07]); decrease activities: OR 2.22 [1.28-3.85]); apply med cream: OR 2.27 (1.38-3.73]). Use of prayer more likely to be perceived as efficacious in B (OR 1.93 [1.19-3.14]).
Non-VA Studies
Kamath; 2010^77^ | 2004 | Cohort/ Case-control; Consecutive patients; Not specified | 185; N/A | Single institution | B, Non-B/ Medical Record Review | TKR | outcome of procedure, outcome expectations of surgery | B men had longer delays to presentation than non B men (29.9 months [CI 17.2, 42.6] vs 20.0 months [CI 4.4, 35.6]) and worse 2-year KSS (89.6 months [CI 85.0, 94.2] vs 94.1 months [CI 91.2, 97.0]). B women had worse final ROM and similar final gains in ROM (postoperative minus preoperative) controlling for confounders.
Slover; 2010^78^ | 1997-2006 | Cross-sectional; Consecutive patients; Not specified | 3542; 0 | Single institution | W, B, H/ Self-reported | TKR, THR | preop jt function | Lower function with Harris Hip Scores 4.9 (P<.0001) and 8.77 (P<.001) and Knee Society Scores that were 6.03 (P<.06) and 12.8 (P<.001) points lower in B and H patients than W.
Suarez-Almazor; 2010^73^ | 999 | Qualitative; Unclear; Not specified | 37, 0 | Single institution | W, B, H/ Self-reported | TKR | willingness to consider surgery, outcome expectations of surgery, TKR Knowledge, Current prob knee OA | Attitudes and beliefs of surgical decision-making were primarily based on personal experiences. Personal experiences had both positive or negative impacts and included concerns about outcomes following surgery and possible complications. B did not have more concerns or fewer expectations.
Epstein; 2010^81^ | 2001-2004 | Cross-sectional; Pop-based; Not specified | 25598, 0 | NYC discharge data | W, B, H, A/ Admin. data | THR | use HVH (hospital), use HVH (surgeon) receipt of procedure | B, Asians, H were more likely to be operated for TJR in low volume hospitals by low volume surgeons than whites (25.3%, 35.0%, 23.0% and 15.6%; P<.001)
Lavernia; 2010^74^ | 2000-2002 | Cohort/ Case-control; Convenience; Not specified | 331; 0 | Single institution | W, B/Self-reported | TKR, THR | outcome of procedure, fear of surgery, physical function | B patients had greater fear before joint arthroplasty compared with W. After surgery, B had higher fear subscale, cognitive subscale, and total PASS score (WOMAC physical function, pain, and total scores.
Berges; 2008^80^ | 2002-2003 | Cohort/ Case-control; Pop-based; N/A | 69793; NR | National | W, B, H, A/ Admin. data | THR | outcome of procedure | B and H had higher odds of discharge to home following hip replacement (B: OR 1.23 [1.107-1.41] and H: OR 1.5 [1.15-1.99]). B not significant. Men had higher odds of discharge to home (OR 1.18 [1.01-1.17]). Mean functional status change not predictive of discharge disposition (OR 1.10 [1.10-1.11])
Steel; 2008^62^ | 1998, 2000, 2002 | Cohort/ Case-control; Pop-based; Not specified | 14807; NR | National | W, B/Self-reported | TKR, THR | need for surgery, receipt of procedure | Lower receipt of TJR in B (vs W: OR 0.47; CI 0.26–0.83) or less educated (0.65; 0.44–0.96). Differences not explained by employment, access, family responsibilities, disability, living alone, comorbidity, or excluding younger than Medicare.
Hanchate; 2008^57^ | 1994-2004 | Cohort/ Case-control; Pop-based; Not specified | 18439; NR | National | W, B, H/ Self-reported | TKR | receipt of procedure | B men (relative to W women) were less likely (OR 0.46 (0.28–0.78), [P < 0.05]) to receive TKA. Adjusting for economic factors, racial/ethnicity, TKA rates differences for women disappeared, while remaining large for B men (OR 0.56 [0.33–0.95]).
Kroll; 2007^76^ | 999 | Qualitative; Convenience; Not specified | 37; NR | Single institution | W, B, H/ Self-reported | TKR | attitudes and beliefs about TKR | Knee OA is experienced differently by ethnicity and groups, and perceptions of the cause of knee OA vary. Trust is important for H considering TKA. Economic factors do not constrain the decision to have surgery.
SooHoo; 2011^83^ | 1995-2005 | Cross-sectional; Pop-based; N/A | 138399; NR | OSHDD (California input database) | W, B, H, A/ Admin. data | THR | receipt by hospital volume | H had higher RRR [3.52 (95% [CI], 2.61-4.74; p < .001)] for the use of a low-volume hospital when compared to W. B (RRR, 1.78; p = .023) and Asian patients (RRR, 1.77; p = .048) also had a higher RRR compared to W for the use of low-volume hospitals
Liu; 2006^82^ | 2000-2004 | Cross-sectional; Pop-based; N/A | 1E+05; NR | OSHDD (California input database) | W, B, H, A/ Admin. data | TKR | receipt by hospital volume | B, Asians, and H were more likely to have TKR at low volume hospital than W (RR=1.32 [95% CI 1.25-1.39], RR=1.72 [95% CI 1.60-1.81], RR=1.64 [95% CI 1.58-1.69])
Byrne; 2006^84^ | 999 | Cross-sectional; Random digit dialing; Not specified | 391; NR | Single institution | W, B, H/ Self-reported | TKR | willingness to consider surgery | B less likely to chose surgery than W (OR 0.63 [CI 0.42, 0.93]). Women and older patients were also less likely to choose surgery (OR 0.69 [0.51, 0.94], OR 0.98 [0.97, 0.99]). Larger reductions in negative symptoms with surgery increased the likelihood of choosing surgery. No difference between the public and patients, and no effect of income level was noted.
Suarez-Almazor; 2005^69^ | 2001-2002 | Cross-sectional; Pop-based; N/A | 198; 0 | Single institution | W, B, H/ Self-reported | TKR | recommendation for procedure, willingness to consider surgery, outcome expectations of surgery, preferences for surgery, familiarity of surgery | Physician more likely to discuss TKR with B (27%), 15% W, 11% H (P=.04). More W than minorities (B and H combined) considered TKR (42% vs 28%; P=.04). No differences between B, H, W being familiar with TKR.
Figaro; 2005^70^ | 999 | Cross-sectional; Convenience; 104/114 | 94; 0 | Harlem | B/ Self-reported | TKR | outcome expectations of surgery | In B with high rate of severe OA (mean QoL 7.6 ±1.7), few (36%) believed TKR would improve knee pain; and 45% felt surgery would not improve their health.
Byrne; 2004^85^ | 2001 | Cross-sectional; Pop-based; 23% | 193; 0 | Harris County | W, B, H/ Self-reported | TKR | willingness to pay | Willingness to pay (WTP) as a percentage of income was lowest for B (16.7% for mild OA) as compared to 32.9% W, 26.4% H. Controlling for income, differences in WTP between B and W were significant in multivariate regression analyses, whereas values for H and W were not.
Figaro; 2004^71^ | 999 | Qualitative; Convenience; Not specified | 94; 0 | Harlem | B/ Self-reported | TKR | outcome expectations of surgery, briefs and goals surgery, pref stay in current state, relationship w specialist | Content analyses identified 6 themes: preference for natural remedies, negative expectations of surgery, beliefs about God's control, preference for continuing in their current state, relationships with specialists, and fear of surgery or death.
Chang; 2004^72^ | 1998-1999 | Qualitative; Consecutive; N/A | 37; 0 | Single institution | W, B/Self-reported | TKR | concern about surgery | B women asked the most questions about criteria for TKR; W women asked about drawbacks from surgery; W men asked about devices; B men asked about financial issues and insurance coverage. Only W asked about intraoperative issues. W women asked about recuperation, functional recovery and pain, B women asked about long-term outcomes and support after surgery. W men asked about QOL and B men asked no questions. W men had greatest factual knowledge about surgery.
Ottenbacher; 2003^79^ | 1994-1998 | Cross-sectional; Pop-based; N/A | 12328; NR | 4DSMR, national | W, B, H, A/ Two or more sources | TKR, THR | outcome of procedure | W and B were (P <0.05) more likely to be discharged home alone and responsible for their own care than Asian or H. 36% H after THA or TKA received inpatient medical rehabilitation 58% W, 67% B, and 56% Asians.
Blake; 2002^75^ | 999 | Cross-sectional; Pop-based; 44% | 970; 0 | Medicare Manhattan | W, B/ Two or more sources | hip/knee surgery | Social network, Perception of benefit of arthritis treatment | 42% B compared 65% W reported knowing someone who had surgery for hip or knee pain (P<.0001). B less likely that W to report that surgery had helped someone they knew with hip or knee pain (but not significant). B more likely to have sought care in ER/clinic 22% vs 9%, P<.005) and less likely to have seen an orthopedic surgeon 3% vs 15%, P<.0001). No racial differences in use of self-treatments (OTC, herbs PT, health/cold)
Wilson; 1994^11^ | 1980-1988 | Cross-sectional; Pop-based; N/A | over 3000; NR | NHANES, Medicare | W, B/ Admin. data | TKR | receipt of procedure, Rate of OA | Prevalence of symptomatic OA knee was lower (but not significant) in W compared to B (men OR .39 [.13-1.14] and women OR .78 [.34-1.80]). Racial differences in TKR were consistent across income levels and were unexplained by B having operations at an earlier age or using competing procedures.

* No data denoted as NR or 999

** W= White; B= Black; H= Hispanic; A=Asian

*** TKR=Total Knee Replacement; THR=Total Hip Replacement

Key Question 3/ Generation 3 Evidence Table

Author; Date | Data Dates^*^ | Study Type | Total pop; VA pop^*^ | Data Source | Race^**^/ How determined | Joint Discussed^***^ | Outcomes | Results
Weng; 2007^44^ | 999 | Experimental; Convenience; Not specified | 64; 64 | VA | W,B/Self-reported | TKR | Willingness to consider surgery, outcome expectations of surgery willingness to consider surgery, knowledge of surgery, alternative treatment | At baseline, 13% W and 29% B were willing to consider surgery (P <0.12); after intervention, 13% W and 33% B were willing to consider surgery (P <0.06).

* No data denoted as NR or 999

** W= White; B= Black; H= Hispanic; A=Asian

*** TKR=Total Knee Replacement; THR=Total Hip Replacement