# NEWCASTLE OTTAWA SCALE CRITERIA USED IN QUALITY ASSESSMENT

## Selection

1. Representativeness of the exposed cohort
2. Ascertainment of exposure
3. Demonstration that outcome of interest was not present at start of study

## Comparability

1. Comparability of cohorts on the basis of the design or analysis

## Outcome

1. Assessment of outcome
2. Was follow-up long enough for outcomes to occur
3. Adequacy of follow up of cohorts