# SEARCH STRATEGY

DATABASE SEARCHED:

PubMed

TIME PERIOD COVERED: 1966-2010

LANGUAGE:

ENGLISH

SEARCH STRATEGY:

arthroplasty, replacement, hip OR arthroplasty, replacement, knee OR arthritis/surgery OR osteoarthritis, knee/surgery OR osteoarthritis, hip/surgery OR (hip AND surger*( OR (knee AND surger*) OR (joint AND replac*) OR (knee AND replac*) OR (hip AND replac*) OR (joint AND arthroplast*) OR (hip AND arthroplast*) OR (knee AND arthroplast*)

AND

minority groups OR african americans OR hispanic americans OR african continental ancestry group OR racial OR ethnic OR minorities OR gender OR sex OR age[ti] OR age distribution

AND

disparity OR disparities OR difference* OR variation*