# SUMMARY AND DISCUSSION

## Key Question #1

Our search revealed that the largest number of published studies pertaining to IRBs deal with the challenges of getting IRB approval for multi-site research studies and defining when quality improvement initiatives are considered research (these two topics account for 60 percent of the articles we identified). The VA has recently implemented national policies in both of these areas, designed to reduce complexity and uncertainty for researchers while maintaining appropriate safeguards for research participants.

Of the remaining studies, the next most common topic of study was COI, which thus became the focus of Key Question #2. A modest number of studies assessed payments to providers or patients for participating in research; payment policies varied widely across these studies and little relationship was identified between the time expected for patient involvement and the payment.

We also identified a modest number of published studies about the ethics of genetic studies, which is perhaps surprising given the degree of interest in the topic in both professional and lay audiences.

## Key Question #2

With regard to COI, we identified a modest number of published studies, almost all of them descriptive and some with substantial limitations (such as low survey response rates or geographic restriction of the sample to a small number of sites). There literature on investigator COI is much richer than that on IRB member COI. Nevertheless, the available evidence indicates potentially worrisome variation in practice across sites. Variation exists in four domains:

1. Who needs to disclose?
  Which members of the research project need to provide COI disclosures? This group could include principal investigator(s), co-investigators, research assistants, and other research staff.
2. What needs to be disclosed?
  This category includes direct financial interests, but also indirect financial support such as support for travel to attend meetings or non-financial conflicts.
3. How distant a relationship may an individual have with an investigator and still be required to disclose COI? How many people in the investigator’s family are included in the need for disclosure?
  This group nearly always includes a spouse, but could also include children, parents, siblings, or other extended family members.
4. To whom does the information need to be disclosed? The recipient can range from a specific official or committee within the institution’s IRB to research participants.

The challenges raised by each of these domains is that the options within each can multiply quickly, as can be seen in the following chart, using only a few simple categories for who, what, and how distant.

Using only these simple categories provides 36 different ways that institutions can vary in their financial COI policies, without even accounting for the entity to whom should disclosure be made, the thresholds used for many kinds of financial disclosures, and variability in those thresholds ($5,000–$10,000, etc.). Some of the categories are probably clearly not relevant, such as disclosing the non-financial interests of the children/parents of other researchers, whereas others are likely considered mandatory procedures by all academic institutions, such as disclosing direct financial conflicts for the principle investigator of a study. Between these extremes lies much room for variation.

Most of the studies have described variations in policies regarding who and what should be disclosed. The literature on how conflict and non-compliance are managed is particularly thin.

## LIMITATIONS

The main limitation of this review is the identification of the primary literature. This topic is not one easily searched with MeSH or title terms, unlike more typical topics of systematic reviews such as randomized trials for the efficacy of pharmaceuticals. Although our initial search was intentionally broad and identified more than 4,000 titles, we may have missed some relevant, original studies. During peer review, a number of additional articles or searches were suggested, but pursuing these did not yield additional research articles. The second limitation is the aggregate limitation in the studies we did identify. Many suffered from poor response rates or limited populations, and drawing broad generalizable conclusions is challenging, beyond the general conclusion of variability in certain domains.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Maintaining high ethical standards of conduct in research, both for the investigator and for IRBs, is a high prority for VA, and not one where VA can or should merely react to problems when they are identified. Rather, VA should aim that research conducted at all VA insitutions is held to the same high standard, much as it has done with clinical care over the past 15 years. To do so, VA should:

1. Conduct a descriptive study of current COI practices for investigators and IRB members at all VA facilities,
2. Use this information to determine which areas of current practices have unjustifiable levels of variation across sites,
3. Convene stakeholders to determine best practices for these processes,
4. Create VA-wide policy about these practices, and
5. Monitor implementation across facilities.

As an example, right now it is unknown whether VA facilities vary across the four dimensions of “who should disclose,” “what to disclose,” “how distant must an individual be related to an investigator to avoid disclosure,” and “to whom should COI be disclosed.” VA facilities may vary, possibly greatly, in these dimensions. VA has striven to provide, and patients have come to expect, one high standard of clinical care no matter which VA facility they visit. It is unreasonable for Veterans to expect differing ethical standards of research across VA facilities.

Research-informed policy can ensure that COI disclosure be made as standard as clinical care, while allowing local flexibility when it is justified. Implicit in this statement is that defining standard COI policies, while a necessary condition, is not sufficient. Monitoring implementation is critical. AAHRPP has attempted to institute a common standard across VA facilities (at least those that are accredited) with response to a single disclosure threshold, disclosure from all individuals involved in the research, and management plans. One challenge is as a government agency VA must follow the government-wide ethics regulations that state federal employees may not have financial interests that relate to their work. All VA IRBs, that are accredited, have conflict of interest policies.

After this uniformity is accomplished, the next step will be to try and provide national VA guidelines on managing COI for individuals (investigators) and IRBs. While preservation of local autonomy is important for providing insitutions with the flexibility they need, some system-wide principles would be useful to help local sites inform COI management decisions. Non-financial COI will also need to be addressed at some point. Given the current imprecision with which non-financial conflicts are defined, the VA would best defer this topic until a greater degree of consensus is reached in the scientific community on how non-financial conflicts are defined.

Lastly, since many VA insitutions that conduct research have university affiliates, a potential complicating factor is the lack of harmony between VA COI and that of these university affliates.