# RESULTS

## LITERATURE FLOW

We reviewed 4,302 titles and abstracts from the electronic search and an additional 490 from related searches, for a total of 4,792 references. After applying inclusion/exclusion criteria at the title and abstract levels, we excluded 4,327 references. We retrieved 163 full-text articles for further review and excluded another 47 references. We then categorized the remaining 116 included studies by the issue addressed. Issues were not mutually exclusive, and two articles overlapped between the genetics and COI groups. Figure 1 details the exclusion criteria and the number of references related to each of the topics.

Figure 1 Literature Flow

## KEY QUESTION #1 What has been published regarding the IRB and each of the following issues: Quality improvement initiatives conducted as research studies and therefore requiring IRB approval; Managing conflict of interest; Studies requiring approval of multiple IRBs; Genetic issues; Payment to research participants or health care professionals

We describe here the results of the brief review we performed. Our goal was to assess the state of the literature on issues pertaining to IRBs and to identify the issue with the largest body of research for which no current VA policy exists.

### MULTISITE INSTITUTIONAL REVIEW BOARD CHALENGES

We identified 41 articles that dealt with the challenges of having to submit a research protocol to IRBs (Table 1) at multiple institutions.16–56 Most of these were descriptive studies of how the same application was reviewed by different IRBs. In general these studies reported a great deal of variability in the ways the same protocol was reviewed by IRBs at different institutions, and the resources and time lost by investigators dealing with these multiple, and occasionally conflicting requests from different IRBs. VA has recently implemented a process whereby multisite VA studies can be reviewed by a single, centralized IRB. Consequently, this topic was not an area where a detailed review would be most helpful to VA.

Table 1 Multisite Institutional Review Board Challenges Articles

Multisite Institutional Review Board Challenges
Angell E, Sutton AJ, Windridge K, Dixon-Woods M. Consistency in decision making by research ethics committees: a controlled comparison. J Med Ethics 2006;32:662–4.^16^
Blustein J, Regenstein M, Siegel B, Billings J. Notes from the field: jumpstarting the IRB approval process in multicenter studies. Health Serv Res 2007;42:1773–82.^17^
Burman W, Breese P, Weis S, Bock N, Bernardo J, Vernon A. The effects of local review on informed consent documents from a multicenter clinical trials consortium. Control Clin Trials 2003;24:245–55.^18^
Burman WJ, Reves RR, Cohn DL, Schooley RT. Breaking the camel’s back: multicenter clinical trials and local institutional review boards. Ann Intern Med 2001;134:152–7.^19^
Christie DR, Gabriel GS, Dear K. Adverse effects of a multicentre system for ethics approval on the progress of a prospective multicentre trial of cancer treatment: how many patients die waiting? Intern Med J 2007;37:680–6.^20^
Dilts DM, Sandler AB. Invisible barriers to clinical trials: the impact of structural, infrastructural, and procedural barriers to opening oncology clinical trials. J Clin Oncol 2006;24:4545–52.^21^
Dyrbye LN, Thomas MR, Mechaber AJ, Eacker A, Harper W, Massie FS, Jr., Power DV, Shanafelt TD. Medical education research and IRB review: an analysis and comparison of the IRB review process at six institutions. Acad Med 2007;82:654–60.^22^
Dziak K, Anderson R, Sevick MA, Weisman CS, Levine DW, Scholle SH. Variations among Institutional Review Board reviews in a multisite health services research study. Health Serv Res 2005;40:279–90.^23^
Edwards SJ, Stone T, Swift T. Differences between research ethics committees. Int J Technol Assess Health Care 2007;23:17–23.^24^
Elwyn G, Seagrove A, Thorne K, Cheung WY. Ethics and research governance in a multicentre study: add 150 days to your study protocol. BMJ 2005;330:847.^25^
Enzle ME, Schmaltz R. Ethics review of multi-centre clinical trials in Canada. Health Law Rev 2005;13:51–7.^26^
Ezzat H, Ross S, von Dadelszen P, Morris T, Liston R, Magee LA. Ethics review as a component of institutional approval for a multicentre continuous quality improvement project: the investigator’s perspective. BMC Health Serv Res 2010;10:223.^27^
Gold JL, Dewa CS. Institutional review boards and multisite studies in health services research: is there a better way? Health Serv Res 2005;40:291–307.^28^
Green LA, Lowery JC, Kowalski CP, Wyszewianski L. Impact of institutional review board practice variation on observational health services research. Health Serv Res 2006;41:214–30.^29^
Greene SM, Geiger AM. A review finds that multicenter studies face substantial challenges but strategies exist to achieve Institutional Review Board approval. J Clin Epidemiol 2006;59:784–90.^30^
Greene SM, Geiger AM, Harris EL, Altschuler A, Nekhlyudov L, Barton MB, Rolnick SJ, Elmore JG, Fletcher S. Impact of IRB requirements on a multicenter survey of prophylactic mastectomy outcomes. Ann Epidemiol 2006;16:275–8.^31^
Helfand BT, Mongiu AK, Roehrborn CG, Donnell RF, Bruskewitz R, Kaplan SA, Kusek JW, Coombs L, McVary KT. Variation in institutional review board responses to a standard protocol for a multicenter randomized, controlled surgical trial. J Urol 2009;181:2674–9.^32^
Hicks SC, James RE, Wong N, Tebbutt NC, Wilson K. A case study evaluation of ethics review systems for multicentre clinical trials. Med J Aust 2009;191:280–2.^33^
Koski G, Aungst J, Kupersmith J, Getz K, Rimoin D. Cooperative research ethics review boards: a win-win solution? IRB 2005;27:1–7.^34^
McWilliams R, Hoover-Fong J, Hamosh A, Beck S, Beaty T, Cutting G. Problematic variation in local institutional review of a multicenter genetic epidemiology study. JAMA 2003;290:360–6.^35^
Menikoff J. The paradoxical problem with multiple-IRB review. N Engl J Med 2010;363:1591–3.^36^
Newgard CD, Hui SH, Stamps-White P, Lewis RJ. Institutional variability in a minimal risk, population-based study: recognizing policy barriers to health services research. Health Serv Res 2005;40:1247–58.^37^
Olver IN. A case study evaluation of ethics review systems for multicentre clinical trials. Med J Aust 2010;192:293.^38^
Pogorzelska M, Stone PW, Cohn EG, Larson E. Changes in the institutional review board submission process for multicenter research over 6 years. Nurs Outlook 2010;58:181–7.^39^
Racine E, Bell E, Deslauriers C. Canadian research ethics boards and multisite research: experiences from two minimal-risk studies. IRB 2010;32:12–8.^40^
Ravina B, Deuel L, Siderowf A, Dorsey ER. Local institutional review board (IRB) review of a multicenter trial: local costs without local context. Ann Neurol 2010;67:258–60.^41^
Rikkert MG, Lauque S, Frolich L, Vellas B, Dekkers W. The practice of obtaining approval from medical research ethics committees: a comparison within 12 European countries for a descriptive study on acetylcholinesterase inhibitors in Alzheimer’s dementia. Eur J Neurol 2005;12:212–7.^42^
Rose CD. Local vs central institutional review boards for multicenter studies. JAMA 2003;290:2126; author reply 2126–7.^43^
Saginur R, Dent SF, Schwartz L, Heslegrave R, Stacey S, Manzo J. Ontario Cancer Research Ethics Board: lessons learned from developing a multicenter regional institutional review board. J Clin Oncol 2008;26:1479–82.^44^
Sarson-Lawrence M, Alt C, Mok MT, Dodds M, Rosenthal MA. Trust and confidence: towards mutual acceptance of ethics committee approval of multicentre studies. Intern Med J 2004;34:598–603.^45^
Shelby-James T, Agar MR, Currow DC. A case study evaluation of ethics review systems for multicentre clinical trials. Med J Aust 2010;192:292.^46^
Sherwood ML, Buchinsky FJ, Quigley MR, Donfack J, Choi SS, Conley SF, Derkay CS, Myer CM, 3rd, Ehrlich GD, Post JC. Unique challenges of obtaining regulatory approval for a multicenter protocol to study the genetics of RRP and suggested remedies. Otolaryngol Head Neck Surg 2006;135:189–96.^47^
Silverman H, Hull SC, Sugarman J. Variability among institutional review boards’ decisions within the context of a multicenter trial. Crit Care Med 2001;29:235–41.^48^
Stair TO, Reed CR, Radeos MS, Koski G, Camargo CA. Variation in institutional review board responses to a standard protocol for a multicenter clinical trial. Acad Emerg Med 2001;8:636–41.^49^
Stark AR, Tyson JE, Hibberd PL. Variation among institutional review boards in evaluating the design of a multicenter randomized trial. J Perinatol 2010;30:163–9.^50^
Tully J, Ninis N, Booy R, Viner R. The new system of review by multicentre research ethics committees: prospective study. BMJ 2000;320:1179–82.^51^
Vick CC, Finan KR, Kiefe C, Neumayer L, Hawn MT. Variation in Institutional Review processes for a multisite observational study. Am J Surg 2005;190:805–9.^52^
Wagner TH, Bhandari A, Chadwick GL, Nelson DK. The cost of operating institutional review boards (IRBs). Acad Med 2003;78:638–44.^53^
Wagner TH, Cruz AM, Chadwick GL. Economies of scale in institutional review boards. Med Care 2004;42:817–23.^54^
Wagner TH, Murray C, Goldberg J, Adler JM, Abrams J. Costs and benefits of the national cancer institute central institutional review board. J Clin Oncol 2010;28:662–6.^55^
Yawn BP, Graham DG, Bertram SL, Kurland MJ, Dietrich AJ, Wollan PC, Brandt EC, Huff JM, Pace WD. Practice-based research network studies and institutional review boards: two new issues. J Am Board Fam Med 2009;22:453–60.^56^

#### When Quality Improvement Initiatives Are Considered Research

Quality improvement is an increasingly important activity for health care organizations and also the subject of scholarly activity. Questions have been asked about what quality improvement activities constitute “research” and would therefore require approval and oversight by an IRB.57,60 This issue was highlighted by the controversy over the Keystone Intensive Care Unit project, where a quality improvement project to decrease bloodstream infections was considered by the Johns Hopkins IRB as “exempt” and later over-ruled by the Office for Human Research Protection, which subsequently amended their ruling. 61

More recently, VA has developed its own definition of what constitutes “research” for this purpose (Table 2).

Table 2 Excerpts from VHA Handbook 1508.05

[underlined: Generalizable Knowledge]: Information that is designed to expand the knowledge base of a scientific discipline (or other scholarly field of study).
[underlined: Operations Activities]: Operations activities are certain administrative, financial, legal, quality assurance, quality improvement, and public health endeavors that are necessary to support VHA’s missions of delivering health care to the nation’s Veterans, conducting research and development, performing medical education, and contributing to national emergency response. VHA operations activities include (but are not limited to):; 1. Conducting quality assessment and improvement activities; systems redesign activities; population-based activities relating to improving health, ensuring safety, or reducing health care costs; and case management and care coordination.; 2. Reviewing the competence or qualifications of health care professionals; evaluating provider and health plan performance; training health care and non-health care professionals; and accreditation, certification, licensing, or credentialing activities.; 3. Underwriting and other activities relating to the creation, renewal, or replacement of a contract of health insurance or health benefits and ceding, securing, or placing a contract for reinsurance of risk relating to health care claims.; 4. Conducting or arranging for medical review, legal analyses, or auditing services, including fraud and abuse detection and compliance programs.; 5. Business planning and development, such as conducting cost-management and planning analyses related to managing and operating an entity.; 6. Business management and general administrative activities.
[underlined: Research]: Research is a systematic investigation (including research development, testing, and evaluation) [underlined: designed] to develop or contribute to generalizable knowledge by [underlined: expanding the knowledge base of a scientific discipline] (or other scholarly field of study). NOTE: Research typically involves the testing of concepts by the scientific method of formulating a hypothesis or research question, systematically collecting and recording relevant data, and interpreting the results in terms of the hypothesis or question to [underlined: expand the knowledge base of a field of study]. Research is further discussed in the Federal Policy (Common Rule) for the Protection of Human Subjects at 38 CFR Part 16; in VHA Directive 1200; and in VHA Handbooks 1200.01 and 1200.05.
[underlined: Systematic Investigation]: A systematic investigation is an activity that is planned in advance and that uses data collection and analysis to answer a question. Although research must include systematic investigation, many [underlined: non-research] activities also include systematic investigation. Systematic investigation does not, in and of itself, define research. Examples of systematic investigations, which [underlined: may or may not] constitute research, include (but are not limited to) activities involving:; 1. Questionnaires or surveys; 2. Observations; 3. Focus groups; 4. Interviews; 5. Analyses of existing data; 6. Analyses of biological specimens; 7. Medical chart reviews; 8. Epidemiologic reviews or analyses; 9. Program evaluations; 10. Quality assessment, quality improvement, and quality management; 11. Interventional studies; 12. Clinical trials

These points can also be summed up thus (text courtesy of Mi-Fu Tsan):

Health care operations activities such as quality assurance and quality improvement projects differ from research in that health care operations activities are specifically designed to support the operations of a health care institution, while research is specifically designed to contribute to generalizable knowledge (i.e., to expand the knowledge base of a scientific discipline or other scholarly field of study). Both health care operations activity and research utilize systematic investigation to achieve their objectives. Similar to research, the results of health care operations activity may be published in scientific journals and ultimately expand scientific knowledge base. Thus, neither systematic investigation nor publication effectively distinguishes health care operations activity from research. However, when a health care operations activity goes beyond its purpose of supporting the operations of a health care institution by adding elements specifically designed to expand the knowledge base of a scientific discipline or other scholarly field of study, the activity constitutes research.

We identified 31 publications on this issue (see Table 3).14, 57–60, 62–87 As VA has already developed policy in this area, this question was not an area for which a detailed review would be helpful.

Table 3 When Quality Improvement Initiatives Are Considered Research Articles

When Quality Improvement Initiatives Are Considered Research
Taylor, H. A., P. J. Pronovost, et al. (2010). “The ethical review of health care quality improvement initiatives: findings from the field.” Issue Brief (Commonw Fund) 95: 1–12.^14^
Platteborze, L. S., S. Young-McCaughan, et al. (2010). “Performance Improvement/Research Advisory Panel: a model for determining whether a project is a performance or quality improvement activity or research.” Mil Med 175(4): 289–91.^62^ ^Platteborze^
Junod, V. and B. Elger (2010). “Retrospective research: What are the ethical and legal requirements?” Swiss Med Wkly 140: w13041.^63^ ^Junod^
Hansson, M. G. (2010). “Need for a wider view of autonomy in epidemiological research.” BMJ 340: c2335.^64^ ^Hansson^
Guta, A., M. G. Wilson, et al. (2010). “Are we asking the right questions? A review of Canadian REB practices in relation to community-based participatory research.” J Empir Res Hum Res Ethics 5(2): 35–46.^65^ ^Guta^
Goldberg, M. S. (2010). “The intersection of sound principles of environmental epidemiologic research and ethical guidelines and review: an example from Canada of an environmental case-control study.” Rev Environ Health 25(2): 147–60.^66^
Dokholyan, R. S., L. H. Muhlbaier, et al. (2009). “Regulatory and ethical considerations for linking clinical and administrative databases.” Am Heart J 157(6): 971–82.^67^
Savel, R. H., E. B. Goldstein, et al. (2009). “Critical care checklists, the Keystone Project, and the Office for Human Research Protections: a case for streamlining the approval process in quality-improvement research.” Crit Care Med 37(2): 725–8.^68^
Nerenz, D. R. (2009). “Ethical issues in using data from quality management programs.” Eur Spine J 18 Suppl 3: 321–30.^69^
Buchanan, E. A. and E. E. Hvizdak (2009). “Online survey tools: ethical and methodological concerns of human research ethics committees.” J Empir Res Hum Res Ethics 4(2): 37–48.^70^
Willison, D. J., C. Emerson, et al. (2008). “Access to medical records for research purposes: varying perceptions across research ethics boards.” J Med Ethics 34(4): 308–14.^71^
Reynolds, J., N. Crichton, et al. (2008). “Determining the need for ethical review: a three-stage Delphi study.” J Med Ethics 34(12): 889–94.^72^
Miller, F. G. and E. J. Emanuel (2008). “Quality-improvement research and informed consent.” N Engl J Med 358(8): 765–7.^73^
Miller, F. G. (2008). “Research on medical records without informed consent.” J Law Med Ethics 36(3): 560–6.^74^
Lemaire, F. (2008). “Informed consent and studies of a quality improvement program.” JAMA 300(15): 1762; author reply 1762–3.^75^
Hutton, J. L., M. P. Eccles, et al. (2008). “Ethical issues in implementation research: a discussion of the problems in achieving informed consent.” Implement Sci 3: 52.^76^
Chaney, E., L. G. Rabuck, et al. (2008). “Human subjects protection issues in QUERI implementation research: QUERI Series.” Implement Sci 3: 10.^77^
Lynn, J., M. A. Baily, et al. (2007). “The ethics of using quality improvement methods in health care.” Ann Intern Med 146(9): 666–73.^57^
Flicker, S., R. Travers, et al. (2007). “Ethical dilemmas in community-based participatory research: recommendations for institutional review boards.” J Urban Health 84(4): 478–93.^78^
Campbell, B., H. Thomson, et al. (2007). “Extracting information from hospital records: what patients think about consent.” Qual Saf Health Care 16(6): 404–8.^79^
Baily, M. A., M. Bottrell, et al. (2006). “The ethics of using QI methods to improve health care quality and safety.” Hastings Cent Rep 36(4): S1–40.^58^
Ernst, A. A., S. J. Weiss, et al. (2005). “Minimal-risk waiver of informed consent and exception from informed consent (Final Rule) studies at institutional review boards nationwide.” Acad Emerg Med 12(11): 1134–7.^80^
Bodenheimer, T., D. M. Young, et al. (2005). “Practice-based research in primary care: facilitator of, or barrier to, practice improvement?” Ann Fam Med 3 Suppl 2: S28–32.^81^
Stimler, C. (2003). “Quality improvement projects: inaction presents the greatest risk.” Arch Intern Med 163(21): 2648–9; author reply 2649.^82^
Nerenz, D. R., P. K. Stoltz, et al. (2003). “Quality improvement and the need for IRB review.” Qual Manag Health Care 12(3): 159–70.^83^
Lo, B. and M. Groman (2003). “Oversight of quality improvement: focusing on benefits and risks.” Arch Intern Med 163(12): 1481–6.^59^
Lindenauer, P. K., E. M. Benjamin, et al. (2002). “The role of the institutional review board in quality improvement: a survey of quality officers, institutional review board chairs, and journal editors.” Am J Med 113(7): 575–9.^84^
Hirshon, J. M., S. D. Krugman, et al. (2002). “Variability in institutional review board assessment of minimal-risk research.” Acad Emerg Med 9(12): 1417–20.^85^
Doezema, D. and M. Hauswald (2002). “Quality improvement or research: a distinction without a difference?” IRB 24(4): 9–12.^86^
Cassell, J. and A. Young (2002). “Why we should not seek individual informed consent for participation in health services research.” J Med Ethics 28(5): 313–7.^87^
Casarett, D., J. H. Karlawish, et al. (2000). “Determining when quality improvement initiatives should be considered research: proposed criteria and potential implications.” JAMA 283(17): 2275–80.^60^

#### Conflict of Interest

We identified 11 publications that dealt with conflict of interest in research, both potential conflict of interest by investigators and potential conflict of interest by IRB members.13, 88–100 Of the issues we reviewed, this one had the largest body of literature to help inform VA policy. Therefore, we selected it for more detailed review (see Key Question #2).

#### Payment to Patients and Providers

Payments to patients and payments to health care professionals to enroll patients both are a particular type of conflict of interest. We considered them separate from the other COI articles because they seemed distinct from issues about disclosure in the other COI articles. We identified nine publications that dealt with ethical issues regarding compensating patients to participate in research studies or paying heath care professionals to recruit patients into these studies (Table 4).15, 101–108 Two of these articles were opinions or commentaries.103, 107 Four of the articles were descriptive studies about payments to patients. A survey of studies approved in 1997 of 32 “geographically diverse organizations involved in the development, conduct and review of biomedical research” found that 30 (94 percent) paid some participants in clinical studies. About one-third of organizations had written policies or guidelines on payment. Since few written policies exist, standards vary.108 A follow up study assessed policies on the offering of payment to research participants approved by seven academic and four independent IRBs in 1997. Across studies, there was, in general, no indication that the payment was related to procedures to be performed or the time commitment required to participate in the study. The studies indicated a wide variation in the size of payments, ranging from $5 to $2000, with a median of $155.^104^

Table 4 Payment to Patients Articles

Payment to Patients
Brown JS, Schonfeld TL, Gordon BG. “You may have already won..”: an examination of the use of lottery payments in research. IRB 2006;28:12–6.^107^
DeRenzo EG. Coercion in the recruitment and retention of human research subjects, pharmaceutical industry payments to physician-investigators, and the moral courage of the IRB. IRB 2000;22:1–5.^103^
Dickert N, Emanuel E, Grady C. Paying research subjects: an analysis of current policies. Ann Intern Med 2002;136:368–73.^108^
Grady C, Dickert N, Jawetz T, Gensler G, Emanuel E. An analysis of U.S. practices of paying research participants. Contemp Clin Trials 2005;26:365–75.^104^
Hall MA, Friedman JY, King NM, Weinfurt KP, Schulman KA, Sugarman J. Commentary: Per capita payments in clinical trials: reasonable costs versus bounty hunting. Acad Med;85:1554–6.^105^
Raftery J, Bryant J, Powell J, Kerr C, Hawker S. Payment to healthcare professionals for patient recruitment to trials: systematic review and qualitative study. Health Technol Assess 2008;12:1–128, iii.102
Ripley E, Macrina F, Markowitz M, Gennings C. Who’s doing the math? Are we really compensating research participants? J Empir Res Hum Res Ethics 2010;5:57–65.^15^
Ripley E, Macrina F, Markowitz M, Gennings C. Why do we pay? A national survey of investigators and IRB chairpersons. J Empir Res Hum Res Ethics 2010;5:43–56.^101^
Wolf LE. IRB policies regarding finder’s fees and role conflicts in recruiting research participants. IRB 2009;31:14–9.^106^

Two studies by the same investigator assessed the potential reasons for payments to participants. In the first study, a web-based survey of hundreds of IRB chairpersons and investigators (with a 24 percent response rate) presented six hypothetical research scenarios that varied by the time involved, funding source, and risk. Respondents were asked to select what they considered an appropriate payment from a list of possible figures. The results indicate that individuals consider different factors in determining payment for studies.109 A related study found that 60 percent, 54 percent, and 42 percent of respondents recommended only a token payment (none or payment only for parking) for studies involving four phone surveys, a one-visit study for DNA collection via buccal swab, and a cancer treatment trial involving 24 visits, meaning that the time spent by the patient vastly exceeded any compensation.110

Three publications dealt with the practice of paying healthcare professionals for patient recruitment into clinical trials.102, 105, 106 The largest of these was a systematic review that searched standard databases through 2006 and identified a small number of original studies: 3 cross sectional surveys, two studies from primary care, and one study from hospital care. The authors could draw no conclusions from their limited evidence base.111 A second study assessed (from available websites) the policies of 117 IRBs regarding such payments. Only about 25 percent of IRBs had policies about physicians recruiting their own patients for study.106 The last publication was a commentary about the potential hazards of large payments for patient enrollments.105

#### Genetic Studies

We identified eight publications that dealt with potential ethical issues arising from genetic studies that involved the IRB (Table 5).12, 88, 89, 112–116 One article described a 1995 consensus process for recommendations for informed consent for patients participating in genetic studies.113 Another described an anonymous survey of IRB chairpersons (22 percent response rate) that found considerable variation in IRB practices regarding informed consent for genetic studies.115 An in-person survey of Canadian Research Ethic Boards about bio-banks found variability in what was required for the duration of consent.114 Another study characterized the ethical, legal, and social issues unique to genetic database research.116 Another publication analyzed the websites of the IRBs from the top 25 NIH funded medical schools,112 and another presented the findings of a survey of clinical research centers.12 Finally, two studies categorized as genetics studies also dealt with the topic of conflict of interest and are discussed in that section.88, 89

Table 5 Genetic Studies Articles

Genetics
Austin MA, Harding SE, McElroy CE. Monitoring ethical, legal, and social issues in developing population genetic databases. Genet Med 2003;5:451–7.^116^
Clayton EW, Steinberg KK, Khoury MJ, Thomson E, Andrews L, Kahn MJ, Kopelman LM, Weiss JO. Informed consent for genetic research on stored tissue samples. JAMA 1995;274:1786–92.^113^
Gibson E, Brazil K, Coughlin MD, Emerson C, Fournier F, Schwartz L, Szala-Meneok KV, Weisbaum KM, Willison DJ. Who’s minding the shop? The role of Canadian research ethics boards in the creation and uses of registries and biobanks. BMC Med Ethics 2008;9:17.^114^
Lipworth W, Kerridge I. Impediments to “T2” research: are ethics really to blame? Am J Bioeth. 2010;10(8):39–40.^89^
Sofaer N, Eyal N. The diverse ethics of translational research. Am J Bioeth. 2010;10(8):19–30.^88^
White MT, Gamm J. Informed consent for research on stored blood and tissue samples: a survey of institutional review board practices. Account Res 2002;9:1–16.^115^
Wolf LE, Bouley TA, McCulloch CE. Genetic research with stored biological materials: ethics and practice. IRB 2010;32:7–18.^12^
Wolf LE, Lo B. Untapped potential: IRB guidance for the ethical research use of stored biological materials. IRB 2004;26:1–8.^112^

#### Miscellaneous

Eighteen publications were potentially relevant to the IRB’s role in maintaining research integrity, but did not fall into one of the existing categories (Table 6).117–134 These articles represent a mixture of surveys about ethical issues, particularly challenging scenarios that might require special rules (such as practice-based research networks, palliative care, and nursing research) and methods to evaluate the workings of the IRB.

Table 6 Miscellaneous Articles

Miscellaneous
Angell EL, Bryman A, Ashcroft RE, Dixon-Woods M. An analysis of decision letters by research ethics committees: the ethics/scientific quality boundary examined. Qual Saf Health Care 2008;17:131–6.^131^
Barrett R. Strategies for promoting the scientific integrity of nursing research in clinical settings. J Nurses Staff Dev 2010;26:200–5; quiz 260–7.^121^
Campbell EG, Weissman JS, Clarridge B, Yucel R, Causino N, Blumenthal D. Characteristics of medical school faculty members serving on institutional review boards: results of a national survey. Acad Med 2003;78:831–6.^125^
Coleman CH, Bouesseau MC. How do we know that research ethics committees are really working? The neglected role of outcomes assessment in research ethics review. BMC Med Ethics 2008;9:6.^128^
Dixon-Woods M, Angell E, Ashcroft RE, Bryman A. Written work: the social functions of Research Ethics Committee letters. Soc Sci Med 2007;65:792–802.^132^
Kodish E, Stocking C, Ratain MJ, Kohrman A, Siegler M. Ethical issues in phase I oncology research: a comparison of investigators and institutional review board chairpersons. J Clin Oncol 1992;10:1810–6.^122^
Macneil SD, Fernandez CV. Informing research participants of research results: analysis of Canadian university based research ethics board policies. J Med Ethics 2006;32:49–54.^134^
MacNeil SD, Fernandez CV. Attitudes of research ethics board chairs towards disclosure of research results to participants: results of a national survey. J Med Ethics 2007;33:549–53.^133^
Paasche-Orlow MK, Brancati FL. Assessment of medical school institutional review board policies regarding compensation of subjects for research-related injury. Am J Med 2005;118:175–80.^123^
Sacca L. The uncontrolled clinical trial: scientific, ethical, and practical reasons for being. Intern Emerg Med 2010;5:201–4.^120^
Schuppli CA, Fraser D. Factors influencing the effectiveness of research ethics committees. J Med Ethics 2007;33:294–301.^129^
Sirotin N, Wolf LE, Pollack LM, Catania JA, Dolcini MM, Lo B. IRBs and ethically challenging protocols: views of IRB chairs about useful resources. IRB 2010;32:10–9.^119^
Stevens T, Wilde D, Paz S, Ahmedzai SH, Rawson A, Wragg D. Palliative care research protocols: a special case for ethical review? Palliat Med 2003;17:482–90.^124^
Taylor PL. State payer mandates to cover care in US oncology trials: do science and ethics matter? J Natl Cancer Inst 2010;102:376–90.^118^
Weil C, Rooney L, McNeilly P, Cooper K, Borror K, Andreason P. OHRP compliance oversight letters: an update. IRB 2010;32:1–6.^135^
Wichman A, Kalyan DN, Abbott LJ, Wesley R, Sandler AL. Protecting human subjects in the NIH’s Intramural Research Program: a draft instrument to evaluate convened meetings of its IRBs. IRB 2006;28:7–10.^130^
Wolf LE, Croughan M, Lo B. The challenges of IRB review and human subjects protections in practice-based research. Med Care 2002;40:521–9.^126^
Wolf LE, Walden JF, Lo B. Human subjects issues and IRB review in practice-based research. Ann Fam Med 2005;3 Suppl 1:S30–7.^127^

## KEY QUESTION #2 What is the actual evidence regarding the issue with the largest literature which may inform VA policy? A Detailed Review of Conflict of Interest Studies

Conflict of interest (COI) is increasingly recognized as an important aspect of maintaining public trust in medical research. In 2011, in response to lay media reports of a number of federally funded investigators who failed to disclose millions of dollars in support from companies with a financial interest in the outcome of the research, the NIH released regulations revising its earlier 1995 regulations. Medical journals are requiring increasingly detailed disclosure about potential COI, and the disclosure of COI is one of the primary foci of the recent Institute of Medicine report, “Guidelines We Can Trust.” Between 1994 and 2003, 65 of the 77 most-cited clinical trials were financed, partially or completely, with money from industry.136 Researchers conducting trials for which the findings have potential financial consequences (creating competing interests) are significantly more positive towards the results of their investigations than those without such interests. 137 In addition, studies sponsored by pharmaceutical companies are more likely to have outcomes favorable to these sponsors than investigations receiving other funding, and trials funded by for-profit organizations (companies that may incur financial gain or loss depending on the outcome) were more likely to report positive findings than those supported by not-for-profit organizations.138, 139 What makes such observations so compelling is that research findings may serve as promotional material and may influence development and contents of practice guideline.135, 140 In fact, in one study, 87 percent of authors of guidelines had ties with industry that were often not disclosed.141 IRB members, too, have industry ties, with 36 percent of IRB members disclosing some kind of financial relationship with industry.93 Of concern, 15.6 percent of IRB members reported that a protocol had been presented in a biased way by an IRB member with industry ties, and 33 percent of IRBs did not require their members to formally disclose relationships with industry.93

The evidence contained in the 14 studies reviewed in this section is organized into the following categories:

- Goals of Disclosure
- Who has Policies Around Disclosure
- Persons with Interest That Requires Disclosure
- Parties to Whom Disclosure Must be Made
- Managing Disclosure
- Managing Noncompliance
- Implementing the Policies
- Potential Harms of Disclosure

Many studies contributed evidence to more than one category.

### Goals of Disclosure

Investigators used 5 years of data from the NIH Conflict of Interest Notification study to identify six goals of disclosure, particularly when disclosing to potential research subjects. These goals included promoting informed decision making, respecting participants’ perceived right to know, establishing or maintaining trust, minimizing risk of legal liability, deterring troubling financial relationships, and protecting research participants’ welfare.94

In the opinion of these authors, disclosing COI to potential research subjects has three goals:

- promoting autonomy by providing people with information material to making informed decisions about participating in research,
- avoiding legal liability by meeting basic legal or regulatory requirements without hindering research and deterrence, and
- discouraging individuals and institutions from holding conflicts of interest.142

A review of the disclosure policies of 120 academic medical centers found that the majority of the institutions’ policies were most consistent with the goal of avoiding legal liability.92

Another study collected data and feedback from IRB and Conflict of Interest Committee (COIC) officials, individuals with and without health conditions, patients seen in a general medicine primary care clinic, and a multidisciplinary panel of experts and then developed a model disclosure statement. The statement had two versions, one generic and one specific. The generic statement reads:

“The person leading this medical research study might benefit financially from this study. The Institutional Review Board and a committee at ABC University have reviewed the possibility of financial benefit. They believe that the possible financial benefit to the person leading the research is not likely to affect your safety and/or the scientific quality of the study. If you would like more information, please ask the researchers or the study coordinator.” (Page 4)

The specific version of the disclosure statement reads:

“The person leading this medical research study might benefit financially from this study. Specifically, [insert appropriate description from below]. The Institutional Review Board and a committee at ABC University have reviewed the possibility of financial benefit. They believe that the possible financial benefit to the person leading the research is not likely to affect your safety and/or the scientific quality of the study. If you would like more information, please ask the researchers or the study coordinator” (Page 5.)

The descriptions available for insertion included salary support, money received outside of the study, per capita payments, finders’ fees restricted to research uses, unrestricted finders’ fees, a researcher or university holding a patent, and a researcher or university owning equity.96

A study in which investigators, IRB chairs, and a conflict-of-interest committee (COIC) chairs at ten academic medical centers were interviewed found that 75 percent of investigators (n=8) believed that COI should be disclosed to potential research participants in all circumstances, with half of them believing it should depend on the degree of financial relationship involved. Of the IRB chairs (n=23), 61 percent believed that disclosure should be made in all circumstances, 43 percent believed that it should depend on the degree of financial relationship involved, 9 percent believed it depends on the risk to subjects, and 22 percent responded ‘other’ (because these data came from analysis of coded transcripts of interviews, respondents could provide more than one coded response for any category; hence percentages may sum to greater than 100 percent and yield apparently conflicting findings). The majority of COIC chairs (n=14) believed disclosure should occur in all circumstances (57 percent of respondents) and depending on the degree of financial relationship involved (50 percent of respondents).

More than half of the investigators identified the rationale for, or benefits of, disclosure as the right to know, making more informed decisions, and/or transparency/honesty; and somewhat fewer than half of the investigators identified liability, the general warning to participants, building trust, public perceptions or “other.” Of the IRB chairs, more than half identified more informed decision, and transparency/honesty with fewer than half identifying other benefits, including citing regulations as a benefit. Of the COIC chairs, more than half identified making more informed decisions and building trust, with fewer than half citing the other benefits.

As for the information to be disclosed, more than half of the investigators included the funding source, amount of funding, ties between investigator and sponsor, potential consequences of ties between investigator and sponsor, and “other.” Fewer than half thought it necessary to specify that the patient can ask questions. The IRB and COIC chairs answered similarly, except that half (or less) thought potential consequences of ties between investigator and sponsor needed to be reported. The report also summarized beliefs surrounding the timing of the disclosure, with 88 percent of the investigators believing it should be within the informed consent document, compared to 52 percent of the IRB chairs and 29 percent of the COIC chairs.

One fourth of the investigators thought the information should be included in an educational brochure, compared to 4 percent of the IRB chairs and none of the COIC chairs. One fourth of the investigators believed it should be part of the informed consent process, compared to 43 percent of the IRB chairs and COIC chairs. This study documents potentially important differences in the perceived goals of disclosure among these various stakeholders.97

### Who has Policies around Disclosure?

#### Conflicts of Interest among Researchers

On October 1, 1995, the Public Health Service and the National Science Foundation declared guidelines surrounding disclosure of COI. The threshold for disclosure of COI was $10,000 in annual income or equity in a relevant company or five percent ownership of such a company. These guidelines gave research institutions discretion in managing conflicts of interest and required that the existence of conflicts of interest that met this threshold be reported to the funding agency before the funds were used.99

Lo and colleagues reviewed the COI policies of the 10 medical schools receiving the largest amount of funding from NIH (Baylor College, Columbia University, Harvard, Johns Hopkins, the University of Pennsylvania, University of California at Los Angeles, University of California at San Francisco, University of Washington, Washington University at St. Louis, and Yale University). All required disclosure of financial interests, including stock and stock options and income from salary, honoraria, and consulting fees. Five institutions required disclosure of all financial interest, regardless of the value, whereas the rest followed the federal guidelines and required disclosure only of amounts exceeding $10,000. All ten institutions required disclosures to a university official or committee, but only six institutions required disclosure to the IRB, and only two of these six required disclosure to research subjects.100

A national survey of policies on disclosure of COI in biomedical research expanded these data to include responses from medical schools and other research institutions (N=250) that received more than $5 million in total grants annually from the NIH or the National Science Foundation, 47 journals in basic science and clinical medicine, and 16 federal agencies. Of these entities, five medical schools and 10 other research institutions (6 percent of the 250 institutions that responded) reported that they had no policies regarding COI. Among those that did have policies, 91 percent adhered to the federal threshold for disclosure, with 9 percent exceeding (were stricter than) those guidelines. Among the journals, 43 percent (20 journals) reported that they had policies requiring disclosure of COI. Of the 16 federal agencies, four had policies that explicitly addressed COI in extramural research and all but one of the agencies relied primarily on institutional discretion. Within these policies, the specific interests that were required to be disclosed included income (91 percent of policies), equity interest (93 percent), intellectual property (73 percent), finder’s fees (1 percent), fiduciary interest only (57 percent), appearance of conflict (66 percent), support of the research (34 percent), and other in-kind support (44 percent). This survey also assessed when, specifically, disclosure was required: Disclosure was required annually or semiannually in 82 percent, upon a material change creating a new potential for conflicts in 76 percent, when a conflict is anticipated in 57 percent, on application for funding in 63 percent, and on award of funding in 9 percent.99

Another survey compared COI policies of academic and nonacademic research settings by surveying officials at 199 sites that contributed participants to commercially sponsored phase-3 clinical trials published in JAMA or the New England Journal of Medicine in 2006 and 2007. They found that 97 percent of academic medical centers and 87 percent of nonacademic medical centers followed written COI policies, compared to only 44 percent of outpatient non-academic sites. Within these policies, 49 percent of the institutions used a monetary threshold below which there was no review of investigator’s financial relationships; 29 percent of the non-academic medical centers and 16 percent of the non-academic outpatient settings adhered to this policy. This threshold was equal to the NIH threshold in 73 percent of academic medical centers, 68 percent of non-academic medical centers, and 20 percent of non-academic outpatient sites, respectively. Fewer than half of the sites, regardless of type, reported that they reviewed whether per capita payments for conducting research exceeded the reasonable costs of conducting the research.13

#### Conflicts of Interest within an IRB

A study of IRBs from the 121 medical schools that received NIH funding in 2003 found that 74 percent (92/124 one school had 4 IRBs) had written policies that addressed IRB members’ COI. Seventy-nine percent of those institutions with written policies defined what constituted a COI: 10 of these required any financial interest to be disclosed, 23 required anything greater than $10,000 to be disclosed, four stated significant financial interests needed to be disclosed (but did not define the threshold), and 14 had no definition of a financial interest.91

In 2005, an anonymous survey specifically targeted the IRB chairs who serve at the most research-intensive medical institutions in the US. Out of the 211 respondents (of 296 eligible), 68 percent stated that their IRB has a written policy defining a COI, 22 percent stated that their IRB did not, and 9 percent did not know.95

A survey of the policies of academic medical centers was conducted to look specifically for items pertaining to disclosing COI to potential research participants. In this survey, 57 of the 120 academic medical centers (48 percent) mentioned disclosure of COI to potential research subjects. Of these, 58 percent required or suggested verbatim language for the informed consent document. All required disclosure of the study sponsor, but only 38 percent required that the nature of the financial relationship be disclosed. Only 18 percent specified disclosing how funds are allocated, and only 4 percent required notification that the protocol had been reviewed by the COI committee or other administrative body. A few (5 percent) made reference to non-financial interests, and none contained guidelines about disclosing the amount of money involved.92

### Persons with Interest Requiring Disclosure

Little agreement was seen in surveys on which person or entity was required to disclose a COI. All the “top 10” medical schools required disclosure by full-time and part-time faculty and the investigators’ spouses and dependent children.100 One university extended disclosure to “de facto spouses,” parents, siblings, and adult children. Two universities also required disclosure of any “trust, organization, or enterprise” over which the faculty member “exercises a controlling interest.” Four policies applied to all research staff and three other policies applied to selected research staff, generally those with “responsibility for the design, conduct, and reporting of research.” Four policies also applied to trainees.100

In the survey of the policies of 235 medical schools and other research entities, all investigators were required to disclose, but “family” was expanded to include not only the spouse or partner (89 percent) and minor or dependent child (89 percent), but also another household member (32 percent), adult child (23 percent), parent (22 percent), grandchild (6 percent), another relative (15 percent), unspecified family (2 percent) and a trust (6 percent).99

Among policies specific to IRBs, 99 percent referred to all IRB members, and one policy referred only to IRB chairs. In addition, 14 percent of policies extended to IRB staff, 20 percent of policies specified ad hoc reviewers and consultants, and only 4 percent extended to guests. 91

In the study that compared academic and non-academic research sites, 100 percent of the academic medical centers required investigators to report financial relationships in clinical research, whereas 96 percent of the non-academic medical centers and 90 percent of the non-academic outpatient settings required this disclosure. Non-employee investigators were also covered, with the institution reviewing the financial relationships of non-employee investigators in 90 percent of the academic medical centers, 83 percent of the non-academic medical centers, and 67 percent of the non-academic outpatient settings. If the institution did not review these non-employee relationships, another institution or office reviewed them in 100 percent of the academic medical centers, 70 percent of the non-academic medical centers, and 33 percent of the non-academic outpatient settings.13

### Parties to Whom Disclosure Must be Made

#### Conflicts of Interest among Researchers

The reviewed studies often failed to specify the party to whom the disclosure must be made. The study of the policies of the 10 medical schools receiving the largest amount of funding from the NIH found that all 10 required that disclosure of COI be made to a university committee or official “who would either approve the disclosed financial arrangements or ensure that steps were taken to manage, reduce, or eliminate the conflict of interest.” Six of those institutions also required that disclosure of financial interests be made to the IRB. Two of these institutions also required disclosure to be made to research participants. Four institutions required that disclosure be made in presentations and published articles.100

When the survey was expanded to include a larger number of institutions, responses revealed that 100 percent of the medical schools surveyed (235/235) required initial disclosure to some party within the institution, with only one percent requiring initial disclosure to be made to the IRB, eight percent to the funding agency or sponsor, one percent to research subjects, and seven percent to journals. One school also stipulated that disclosure be made to collaborating researchers.99

Interestingly, a separate study that surveyed academic medical centers, explicitly searching for information about disclosing COI to potential research subjects, 48 percent of their policies mentioned such disclosure as a possible strategy for managing conflicts.92

In the study comparing academic and non-academic settings, the IRB had a role in review of investigators’ financial relationships in clinical research in 74 percent of academic medical centers, 73 percent of non-academic medical centers, and 74 percent of non-academic outpatient settings. Other persons or groups with a role in review of investigators financial relationships in clinical research included the COI committee (45 percent, 9 percent, 1 percent respectively); compliance department (5 percent, 2 percent, 0.4 percent); legal department (2 percent, 3 percent, 0.4 percent); research office, department, or committee (4 percent, 8 percent, 1 percent); sponsor (1 percent, 1 percent, 7 percent); board (1 percent, 0, 1 percent); key individual (11 percent, 6 percent, 3 percent); other (10 percent, 3 percent, 1 percent); or no other review (3 percent, 7 percent, 10 percent).13

A national survey of five groups of research stakeholders, including researchers, research officials, bioethicists, editors of journals, and federal agency officials, questioned them about requirements for disclosure of COI to IRBs, research subjects, journals, and funding agencies. Overall, all of these stakeholders gave some level of support to disclosure to IRBs, research subjects, journals, and funding agencies. However, only the bioethicists were strongly supportive of including research participants.98

#### Conflicts of Interest within an IRB

When IRB chairs were surveyed, 62 percent responded that their IRB members reported their industry relationships to the IRB chair, 76 percent of respondents reported to the entire IRB, 53 percent of respondents reported to a group or individual within the organization but separate from the IRB, 7 percent reported to an entity external to the IRB and the institution that it serves, and 2 percent reported to an unnamed ‘other.’95

### Managing Disclosure

Within the policies of the 235 medical schools and other research institutions, disclosure was managed by divestment of interest (62 percent), withdrawal of the investigator from the project (61 percent), disclosure to the IRB or research participants (0 percent), disclosure to the funding agency or sponsor (43 percent), disclosure to journals (2 percent), disclosure to collaborating researchers (1 percent), a modification of research plan (59 percent), monitoring of the project (66 percent), requiring additional peer review (7 percent), or public disclosure (59 percent). Only one of the institutions had a mandatory management method, with the remainder relying on a discretionary management method.99

When IRB chairs were surveyed regarding what occurred following the disclosure of a conflict of interest, management was decided by the IRB chair in 27 percent of the institutions, the entire IRB in 31 percent, a group or individual within the organization but separate from the IRB in 16 percent, a written policy in 13 percent, and the IRB member in 13 percent.95

#### Prohibited Interests

Absolute prohibitions on particular COI were less common. One of the ‘top 10’ institutions prohibits faculty from having stock-options, consulting agreements, and decision-making positions that involved a company sponsoring a study in which the faculty member is participating. Another institution prohibited trading in stock or stock options in the company sponsoring the research or selling the product or device being investigated. Two other institutions did not prohibit but did not allow faculty to participate in research if they had a ‘significant’ financial interest “in the company owning or licensing the product or device being studied.”100

When comparing academic to nonacademic research settings, 30 percent of academic medical centers, 33 percent of non-academic medical centers, and 5 percent of non-academic outpatient settings prohibited consulting; 52 percent, 44 percent, and 82 percent prohibited equity; 30 percent, 33 percent, and 36 percent prohibited per capita payments; and 70 percent, 59 percent, and 36 percent had unspecified ‘other’ prohibitions.

#### Monitoring Compliance

No studies were identified that described how compliance was monitored.

### Managing Noncompliance

Methods of managing non-compliance with a COI policy varied across institutions. In a survey of IRB policies, only 4 of 92 (four percent), discussed what occurs when members failed to comply with the COI policies of their own IRB. One described such actions as reporting the non-compliance to institutional officials with possible removal from the IRB, revocation of the member’s institutional appointment, and potential sanctions from federal oversight agencies. The others mentioned only removal from the IRB.91

When looking at the policies of 235 medical schools and other research entities, the penalty for non-disclosure of COI was termination (46 percent); suspension (20 percent); salary modification (12 percent); non-financial modification, e.g., loss of research space (12 percent); reprimand (28 percent); disqualification from future grant applications (19 percent); notification of funding agency, journal, or both of nondisclosure (42 percent); removal of investigator from project (5 percent); unspecified or nonspecific penalty (46 percent); mandatory penalty (0); or discretionary penalty (100 percent).99

### Implementing the Policies

The majority of these studies assessed the policies in place, most likely assuming that the policy was enforced. Two of the studies assessed how well the policies were implemented when a COI was identified. In a study of a random sample of 893 IRB members, 78 reported that in the previous year, their IRB reviewed at least one protocol for a study sponsored by a company with which they had a relationship, or a competitor of that company. Of these IRB members, 58 percent always disclosed the relationship to an IRB official, 8 percent sometimes did, 12 percent rarely did and 23 percent never did. Of the 62 who were voting members of their IRBs (not all IRB members are voting members), 65 percent reported that they never voted on a protocol for which they had a financial interest, 5 percent rarely did, 11 percent sometimes did, and 19 percent always did.93

An anonymous survey asked IRB chairs, “in hindsight, over the last year, how confident are you that your IRB’s processes and procedures provided the appropriate level of disclosure for every study in which a member-industry relationship existed?” Most were moderately confident (41.5 percent vs. 38.7 percent very confident, 15.1 percent not very confident and 4.1 percent not at all confident). In addition, they were asked to recall what happened when a member had a conflict of interest with industry. For example, 63.8 percent answered that the member always left the room when the protocol was under consideration, 10.6 percent answered that the member ‘never’ left the room, 10.6 percent answered that the member ‘rarely’ left, and 14.9 percent answered that the member ‘usually’ left the room. When asked if that member fully participated in the general discussion, 63 percent answered ‘never,’ 21.7 percent ‘rarely,’ 8.7 percent ‘usually,’ and 6.5 percent ‘always.’ Regarding whether the member voted on the protocol, 100 percent answered ‘never.’ They were also asked to rate their confidence that the IRB managed conflicts correctly in every case. Two percent were ‘not at all confident,’ two percent were ‘not very confident,’ 62 percent were ‘moderately confident,’ and 34 percent were ‘very confident.’95

### Potential Harms of Disclosure

A study for which investigators, IRB chairs, and COIC chairs of ten academic medical centers were interviewed elicited some of the negative effects or barriers to disclosing COI, at least with respect to disclosure to potential research subjects. These barriers included the belief that disclosure “might affect enrollment of participants” (believed by 63 percent (5/8) of investigators, 78 percent (18/23) of IRB chairs, and 79 percent (11/14) of COIC chairs); that disclosure “breaks down trust” (63 percent, 26 percent, and 21 percent, respectively), that disclosure lengthens the informed consent document (38 percent, 26 percent, and 29 percent, respectively); that disclosure lengthens the informed consent process (38 percent, 9 percent, and 0 percent, respectively); that disclosure is unnecessary (25 percent, 0 percent, seven percent, respectively); that disclosure violates issues of investigator privacy (25 percent, 22 percent, and 29 percent, respectively) and that COI are too difficult for research participants to understand (25 percent, 43 percent, and 71 percent, respectively). Some of those surveyed believed there were additional issues, not specified: 62 percent of the investigators, 35 percent of the IRB chairs, and 14 percent of the COIC chairs. Some of those interviewed believed there were no negative effects or barriers to disclosure: 13 percent of the investigators, 4 percent of the IRB chairs, and 29 percent of the COIC chairs.97