# REFERENCES

1 Germany (Territory under Allied occupation 1945- U. S. Zone) Military Tribunals. [from old catalog]. Trials of war criminals before the Nuernberg Military Tribunals under Control Council law no. 10. 1949. Washington. U. S. Govt. Print. Off. 15 v.
2 Association WM. Declaration of Helsinki, 5th (South Africa) amendment. 2000.
3 Beecher HK. Ethics and clinical research. N Engl J Med. 1966;274(24):1354-60. [pmid: 5327352].
4 The National Commission for the Protection of Human Subjects of Biomedical and Behavioral Research, E Department of Health, and Welfare. The Belmont Report: Ethical Principles and Guidelines for the Protection of Human Subjects of Research. 1979. Washington, D.C.
5 Memorandum of the Surgeon General William H. Stewart to the Heads of Institutions Conducting Research with Public Health Grants. USPHS. 1966.
6 Lo B, Field MJ. Institute of Medicine (US). Committee on Conflict of Interest in Medical Research Education and Practice. Conflict of interest in medical research, education, and practice. Washington, DC. National Academies Press. 2009;xxi. 414 p.
7 Bekelman JE, Li Y, Gross CP. Scope and impact of financial conflicts of interest in biomedical research. JAMA. 2003;289(4):454-65. [pmid: 12533125].
8 Institute of Medicine. Conflict of Interest in Medical Research, Education, and Practice. Lo B, Field MJ, editors. Washington, D.C.
9 Cho MK, et al. Policies on faculty conflicts of interst at US universities. JAMA. 2000;284(17):2203-8. [pmid: 11056591].
10 Boyd EA, Lipton S, Bero LA. Implementation of financial disclosure policies to manage conflicts of interest. Health Aff. 2004;23(2):206-14.
11 Boyd EA, Bero LA. Defining financial conflicts and managing research relationships: An analysis of university conflict of interest committee decisions. Sci Eng Ethics. 2007;13:415-435. [pmid: 18008185].
12 Wolf LE, Bouley TA, McCulloch CE. Genetic research with stored biological materials: ethics and practice. IRB. 2010;32(2):7-18. [pmid: 20373733].
13 Weinfurt KP, et al. Oversight of financial conflicts of interest in commercially sponsored research in academic and nonacademic settings. J Gen Intern Med. 2010;25(5):460-4. [pmid: 20186498].
14 Taylor HA, et al. The ethical review of health care quality improvement initiatives: findings from the field. Issue Brief (Commonw Fund). 2010;95:1-12. [pmid: 20726137].
15 Ripley E, et al. Who’s doing the math? Are we really compensating research participants?. J Empir Res Hum Res Ethics. 2010;5(3):57-65. [pmid: 20831421].
16 Angell E, et al. Consistency in decision making by research ethics committees: a controlled comparison. J Med Ethics. 2006;32(11):662-4. [pmid: 17074825].
17 Blustein J, et al. Notes from the field: jumpstarting the IRB approval process in multicenter studies. Health Serv Res. 2007;42(4):1773-82. [pmid: 17610447].
18 Burman W, et al. The effects of local review on informed consent documents from a multicenter clinical trials consortium. Control Clin Trials. 2003;24(3):245-55. [pmid: 12757991].
19 Burman WJ, et al. Breaking the camel’s back: multicenter clinical trials and local institutional review boards. Ann Intern Med. 2001;134(2):152-7. [pmid: 11177319].
20 Christie DR, Gabriel GS, Dear K. Adverse effects of a multicentre system for ethics approval on the progress of a prospective multicentre trial of cancer treatment: how many patients die waiting?. Intern Med J. 2007;37(10):680-6. [pmid: 17894765].
21 Dilts DM, Sandler AB. Invisible barriers to clinical trials: the impact of structural, infrastructural, and procedural barriers to opening oncology clinical trials. J Clin Oncol. 2006;24(28):4545-52. [pmid: 17008693].
22 Dyrbye LN, et al. Medical education research and IRB review: an analysis and comparison of the IRB review process at six institutions. Acad Med. 2007;82(7):654-60. [pmid: 17595560].
23 Dziak K, et al. Variations among Institutional Review Board reviews in a multisite health services research study. Health Serv Res. 2005;40(1):279-90. [pmid: 15663713].
24 Edwards SJ, Stone T, Swift T. Differences between research ethics committees. Int J Technol Assess Health Care. 2007;23(1):17-23. [pmid: 17234012].
25 Elwyn G, et al. Ethics and research governance in a multicentre study: add 150 days to your study protocol. BMJ. 2005;330(7495):847. [pmid: 15817562].
26 Enzle ME, Schmaltz R. Ethics review of multi-centre clinical trials in Canada. Health Law Rev. 2005;13(2–3):51-7. [pmid: 16459414].
27 Ezzat H, et al. Ethics review as a component of institutional approval for a multicentre continuous quality improvement project: the investigator’s perspective. BMC Health Serv Res. 2010;10:223. [pmid: 20673343].
28 Gold JL, Dewa CS. Institutional review boards and multisite studies in health services research: is there a better way?. Health Serv Res. 2005;40(1):291-307. [pmid: 15663714].
29 Green LA, et al. Impact of institutional review board practice variation on observational health services research. Health Serv Res. 2006;41(1):214-30. [pmid: 16430608].
30 Greene SM, Geiger AM. A review finds that multicenter studies face substantial challenges but strategies exist to achieve Institutional Review Board approval. J Clin Epidemiol. 2006;59(8):784-90. [pmid: 16828670].
31 Greene SM, et al. Impact of IRB requirements on a multicenter survey of prophylactic mastectomy outcomes. Ann Epidemiol. 2006;16(4):275-8. [pmid: 16005245].
32 Helfand BT, et al. Variation in institutional review board responses to a standard protocol for a multicenter randomized, controlled surgical trial. J Urol. 2009;181(6):2674-9. [pmid: 19375101].
33 Hicks SC, et al. A case study evaluation of ethics review systems for multicentre clinical trials. Med J Aust. 2009;191(5):280-2. [pmid: 19740053].
34 Koski G, et al. Cooperative research ethics review boards: a win-win solution?. IRB. 2005;27(3):1-7. [pmid: 16021793].
35 McWilliams R, et al. Problematic variation in local institutional review of a multicenter genetic epidemiology study. JAMA. 2003;290(3):360-6. [pmid: 12865377].
36 Menikoff J. The paradoxical problem with multiple-IRB review. N Engl J Med. 2010;363(17):1591-3. [pmid: 20942660].
37 Newgard CD, et al. Institutional variability in a minimal risk, population-based study: recognizing policy barriers to health services research. Health Serv Res. 2005;40(4):1247-58. [pmid: 16033503].
38 Olver IN. A case study evaluation of ethics review systems for multicentre clinical trials. Med J Aust. 2010;192(5):293. [pmid: 20306548].
39 Pogorzelska M, et al. Changes in the institutional review board submission process for multicenter research over 6 years. Nurs Outlook. 2010;58(4):181-7. [pmid: 20637931].
40 Racine E, Bell E, Deslauriers C. Canadian research ethics boards and multisite research: experiences from two minimal-risk studies. IRB. 2010;32(3):12-8. [pmid: 20590052].
41 Ravina B, et al. Local institutional review board (IRB) review of a multicenter trial: local costs without local context. Ann Neurol. 2010;67(2):258-60. [pmid: 20225291].
42 Rikkert MG, et al. The practice of obtaining approval from medical research ethics committees: a comparison within 12 European countries for a descriptive study on acetylcholinesterase inhibitors in Alzheimer’s dementia. Eur J Neurol. 2005;12(3):212-7. [pmid: 15693811].
43 Rose CD. Local vs central institutional review boards for multicenter studies. JAMA. 2003;290(16):2126. author reply 2126–7. [pmid: 14570946].
44 Saginur R, et al. Ontario Cancer Research Ethics Board: lessons learned from developing a multicenter regional institutional review board. J Clin Oncol. 2008;26(9):1479-82. [pmid: 18349399].
45 Sarson-Lawrence M, et al. Trust and confidence: towards mutual acceptance of ethics committee approval of multicentre studies. Intern Med J. 2004;34(11):598-603. [pmid: 15546452].
46 Shelby-James T, Agar MR, Currow DC. A case study evaluation of ethics review systems for multicentre clinical trials. Med J Aust. 2010;192(5):292. [pmid: 20201766].
47 Sherwood ML, et al. Unique challenges of obtaining regulatory approval for a multicenter protocol to study the genetics of RRP and suggested remedies. Otolaryngol Head Neck Surg. 2006;135(2):189-96. [pmid: 16890066].
48 Silverman H, Hull SC, Sugarman J. Variability among institutional review boards’ decisions within the context of a multicenter trial. Crit Care Med. 2001;29(2):235-41. [pmid: 11246299].
49 Stair TO, et al. Variation in institutional review board responses to a standard protocol for a multicenter clinical trial. Acad Emerg Med. 2001;8(6):636-41. [pmid: 11388939].
50 Stark AR, Tyson JE, Hibberd PL. Variation among institutional review boards in evaluating the design of a multicenter randomized trial. J Perinatol. 2010;30(3):163-9. [pmid: 19798046].
51 Tully J, et al. The new system of review by multicentre research ethics committees: prospective study. BMJ. 2000;320(7243):1179-82. [pmid: 10784541].
52 Vick CC, et al. Variation in Institutional Review processes for a multisite observational study. Am J Surg. 2005;190(5):805-9. [pmid: 16226962].
53 Wagner TH, et al. The cost of operating institutional review boards (IRBs). Acad Med. 2003;78(6):638-44. [pmid: 12805049].
54 Wagner TH, Cruz AM, Chadwick GL. Economies of scale in institutional review boards. Med Care. 2004;42(8):817-23. [pmid: 15258484].
55 Wagner TH, et al. Costs and benefits of the national cancer institute central institutional review board. J Clin Oncol. 2010;28(4):662-6. [pmid: 19841324].
56 Yawn BP, et al. Practice-based research network studies and institutional review boards: two new issues. J Am Board Fam Med. 2009;22(4):453-60. [pmid: 19587261].
57 Lynn J, et al. The ethics of using quality improvement methods in health care. Ann Intern Med. 2007;146(9):666-73. [pmid: 17438310].
58 Baily MA, et al. The ethics of using QI methods to improve health care quality and safety. Hastings Cent Rep. 2006;36(4):S1-40. [pmid: 16898359].
59 Lo B, Groman M. Oversight of quality improvement: focusing on benefits and risks. Arch Intern Med. 2003;163(12):1481-6. [pmid: 12824099].
60 Casarett D, Karlawish JH, Sugarman J. Determining when quality improvement initiatives should be considered research: proposed criteria and potential implications. JAMA. 2000;283(17):2275-80. [pmid: 10807388].
61 Baily MA. Harming through protection?. N Engl J Med. 2008;358(8):768-9. [pmid: 18287599].
62 Platteborze LS, et al. Performance Improvement/Research Advisory Panel: a model for determining whether a project is a performance or quality improvement activity or research. Mil Med. 2010;175(4):289-91. [pmid: 20446506].
63 Junod V, Elger B. Retrospective research: What are the ethical and legal requirements?. Swiss Med Wkly. 2010;140:w13041. [pmid: 20349361].
64 Hansson MG. Need for a wider view of autonomy in epidemiological research. BMJ. 2010;340:c2335. [pmid: 20444822].
65 Guta A, et al. Are we asking the right questions? A review of Canadian REB practices in relation to community-based participatory research. J Empir Res Hum Res Ethics. 2010;5(2):35-46. [pmid: 20569148].
66 Goldberg MS. The intersection of sound principles of environmental epidemiologic research and ethical guidelines and review: an example from Canada of an environmental case-control study. Rev Environ Health. 2010;25(2):147-60. [pmid: 20839559].
67 Dokholyan RS, et al. Regulatory and ethical considerations for linking clinical and administrative databases. Am Heart J. 2009;157(6):971-82. [pmid: 19464406].
68 Savel RH, Goldstein EB, Gropper MA. Critical care checklists, the Keystone Project, and the Office for Human Research Protections: a case for streamlining the approval process in quality-improvement research. Crit Care Med. 2009;37(2):725-8. [pmid: 19114910].
69 Nerenz DR. Ethical issues in using data from quality management programs. Eur Spine J. 2009;18(Suppl 3):321-30. [pmid: 19365642].
70 Buchanan EA, Hvizdak EE. Online survey tools: ethical and methodological concerns of human research ethics committees. J Empir Res Hum Res Ethics. 2009;4(2):37-48. [pmid: 19480590].
71 Willison DJ, et al. Access to medical records for research purposes: varying perceptions across research ethics boards. J Med Ethics. 2008;34(4):308-14. [pmid: 18375687].
72 Reynolds J, et al. Determining the need for ethical review: a three-stage Delphi study. J Med Ethics. 2008;34(12):889-94. [pmid: 19043116].
73 Miller FG, Emanuel EJ. Quality-improvement research and informed consent. N Engl J Med. 2008;358(8):765-7. [pmid: 18287598].
74 Miller FG. Research on medical records without informed consent. J Law Med Ethics. 2008;36(3):560-6. [pmid: 18840249].
75 Lemaire F. Informed consent and studies of a quality improvement program. JAMA. 2008;300(15):1762. author reply 1762–3. [pmid: 18854536].
76 Hutton JL, Eccles MP, Grimshaw JM. Ethical issues in implementation research: a discussion of the problems in achieving informed consent. Implement Sci. 2008;3:52. [pmid: 19091100].
77 Chaney E, et al. Human subjects protection issues in QUERI implementation research: QUERI Series. Implement Sci. 2008;3:10. [pmid: 18279507].
78 Flicker S, et al. Ethical dilemmas in community-based participatory research: recommendations for institutional review boards. J Urban Health. 2007;84(4):478-93. [pmid: 17436114].
79 Campbell B, et al. Extracting information from hospital records: what patients think about consent. Qual Saf Health Care. 2007;16(6):404-8. [pmid: 18055882].
80 Ernst AA, et al. Minimal-risk waiver of informed consent and exception from informed consent (Final Rule) studies at institutional review boards nationwide. Acad Emerg Med. 2005;12(11):1134-7. [pmid: 16264084].
81 Bodenheimer T, et al. Practice-based research in primary care: facilitator of, or barrier to, practice improvement?. Ann Fam Med. 2005;3(Suppl 2):S28-32. [pmid: 16049078].
82 Stimler C. Quality improvement projects: inaction presents the greatest risk. Arch Intern Med. 2003;163(21):2648-9. author reply 2649. [pmid: 14638567].
83 Nerenz DR, Stoltz PK, Jordan J. Quality improvement and the need for IRB review. Qual Manag Health Care. 2003;12(3):159-70. [pmid: 12891960].
84 Lindenauer PK, et al. The role of the institutional review board in quality improvement: a survey of quality officers, institutional review board chairs, and journal editors. Am J Med. 2002;113(7):575-9. [pmid: 12459404].
85 Hirshon JM, et al. Variability in institutional review board assessment of minimal-risk research. Acad Emerg Med. 2002;9(12):1417-20. [pmid: 12460847].
86 Doezema D, Hauswald M. Quality improvement or research: a distinction without a difference?. IRB. 2002;24(4):9-12. [pmid: 13678030].
87 Cassell J, Young A. Why we should not seek individual informed consent for participation in health services research. J Med Ethics. 2002;28(5):313-7. [pmid: 12356960].
88 Sofaer N, Eyal N. The diverse ethics of translational research. Am J Bioeth. 2010;10(8):19-30. [pmid: 20694901].
89 Lipworth W, Kerridge I. Impediments to “T2” research: are ethics really to blame?. Am J Bioeth. 2010;10(8):39-40. [pmid: 20694906].
90 Kachuck NJ. Managing conflicts of interest and commitment: academic medicine and the physician’s progress. J Med Ethics. 37(1):2-5. [pmid: 21149321].
91 Wolf LE, Zandecki J. Conflicts of interest in research: how IRBs address their own conflicts. IRB. 2007;29(1):6-12. [pmid: 17855838].
92 Weinfurt KP, et al. Policies of academic medical centers for disclosing financial conflicts of interest to potential research participants. Acad Med. 2006;81(2):113-8. [pmid: 16436571].
93 Campbell EG, et al. Financial relationships between institutional review board members and industry. N Engl J Med. 2006;355(22):2321-9. [pmid: 17135585].
94 Weinfurt KP, et al. Disclosure of financial relationships to participants in clinical research. N Engl J Med. 2009;361(9):916-21. [pmid: 19710491].
95 Vogeli C, Koski G, Campbell EG. Policies and management of conflicts of interest within medical research institutional review boards: results of a national study. Acad Med. 2009;84(4):488-94. [pmid: 19318786].
96 Weinfurt KP, et al. Developing model language for disclosing financial interests to potential clinical research participants. IRB. 2007;29(1):1-5. [pmid: 17364012].
97 Weinfurt KP, et al. Disclosing conflicts of interest in clinical research: views of institutional review boards, conflict of interest committees, and investigators. J Law Med Ethics. 2006;34(3):581-91. 481. [pmid: 17144182].
98 Brody BA, et al. Expanding disclosure of conflicts of interest: the views of stakeholders. IRB. 2003;25(1):1-8. [pmid: 12833897].
99 McCrary SV, et al. A national survey of policies on disclosure of conflicts of interest in biomedical research. N Engl J Med. 2000;343(22):1621-6. [pmid: 11096171].
100 Lo B, Wolf LE, Berkeley A. Conflict-of-interest policies for investigators in clinical trials. N Engl J Med. 2000;343(22):1616-20. [pmid: 11096170].
101 Ripley E, et al. Why do we pay? A national survey of investigators and IRB chairpersons. J Empir Res Hum Res Ethics. 2010;5(3):43-56. [pmid: 20831420].
102 Raftery J, et al. Payment to healthcare professionals for patient recruitment to trials: systematic review and qualitative study. Health Technol Assess. 2008;12(10):1-128. iii. [pmid: 18405468].
103 DeRenzo EG. Coercion in the recruitment and retention of human research subjects, pharmaceutical industry payments to physician-investigators, and the moral courage of the IRB. IRB. 2000;22(2):1-5. [pmid: 11883465].
104 Grady C, et al. An analysis of U.S. practices of paying research participants. Contemp Clin Trials. 2005;26(3):365-75. [pmid: 15911470].
105 Hall MA, et al. Commentary: Per capita payments in clinical trials: reasonable costs versus bounty hunting. Acad Med. 85(10):1554-6. [pmid: 20881671].
106 Wolf LE. IRB policies regarding finder’s fees and role conflicts in recruiting research participants. IRB. 2009;31(1):14-9. [pmid: 19241735].
107 Brown JS, Schonfeld TL, Gordon BG. “You may have already won..”: an examination of the use of lottery payments in research. IRB. 2006;28(1):12-6. [pmid: 16680874].
108 Dickert N, Emanuel E, Grady C. Paying research subjects: an analysis of current policies. Ann Intern Med. 2002;136(5):368-73. [pmid: 11874309].
109 Ripley E, et al. Why do we pay? A national survey of investigators and IRB chairpersons. J Empir Res Hum Res Ethics. 5(3):43-56. [pmid: 20831420].
110 Millum J, Menikoff J. Streamlining ethical review. Ann Intern Med. 2010;153(10):655-7. [pmid: 21079221].
111 Eastman N, Philips B, Rhodes A. Triaging for adult critical care in the event of overwhelming need. Intensive Care Med. 2010;36(6):1076-82. [pmid: 20349037].
112 Wolf LE, Lo B. Untapped potential: IRB guidance for the ethical research use of stored biological materials. IRB. 2004;26(4):1-8. [pmid: 15449408].
113 Clayton EW, et al. Informed consent for genetic research on stored tissue samples. JAMA. 1995;274(22):1786-92. [pmid: 7500511].
114 Gibson E, et al. Who’s minding the shop? The role of Canadian research ethics boards in the creation and uses of registries and biobanks. BMC Med Ethics. 2008;9:17. [pmid: 19014594].
115 White MT, Gamm J. Informed consent for research on stored blood and tissue samples: a survey of institutional review board practices. Account Res. 2002;9(1):1-16. [pmid: 12705242].
116 Austin MA, Harding SE, McElroy CE. Monitoring ethical, legal, and social issues in developing population genetic databases. Genet Med. 2003;5(6):451-7. [pmid: 14614397].
117 Weil C, et al. OHRP compliance oversight letters: an update. IRB. 2010;32(2):1-6. [pmid: 20373732].
118 Taylor PL. State payer mandates to cover care in US oncology trials: do science and ethics matter?. J Natl Cancer Inst. 2010;102(6):376-90. [pmid: 20197514].
119 Sirotin N, et al. IRBs and ethically challenging protocols: views of IRB chairs about useful resources. IRB. 2010;32(5):10-9. [pmid: 21033605].
120 Sacca L. The uncontrolled clinical trial: scientific, ethical, and practical reasons for being. Intern Emerg Med. 2010;5(3):201-4. [pmid: 20169422].
121 Barrett R. Strategies for promoting the scientific integrity of nursing research in clinical settings. J Nurses Staff Dev. 2010;26(5):200-5. quiz 260–7. [pmid: 20885141].
122 Kodish E, et al. Ethical issues in phase I oncology research: a comparison of investigators and institutional review board chairpersons. J Clin Oncol. 1992;10(11):1810-6. [pmid: 1403062].
123 Paasche-Orlow MK, Brancati FL. Assessment of medical school institutional review board policies regarding compensation of subjects for research-related injury. Am J Med. 2005;118(2):175-80. [pmid: 15694904].
124 Stevens T, et al. Palliative care research protocols: a special case for ethical review?. Palliat Med. 2003;17(6):482-90. [pmid: 14526880].
125 Campbell EG, et al. Characteristics of medical school faculty members serving on institutional review boards: results of a national survey. Acad Med. 2003;78(8):831-6. [pmid: 12915379].
126 Wolf LE, Croughan M, Lo B. The challenges of IRB review and human subjects protections in practice-based research. Med Care. 2002;40(6):521-9. [pmid: 12021678].
127 Wolf LE, Walden JF, Lo B. Human subjects issues and IRB review in practice-based research. Ann Fam Med. 2005;3(Suppl 1):S30-7. [pmid: 15928216].
128 Coleman CH, Bouesseau MC. How do we know that research ethics committees are really working? The neglected role of outcomes assessment in research ethics review. BMC Med Ethics. 2008;9:6. [pmid: 18373857].
129 Schuppli CA, Fraser D. Factors influencing the effectiveness of research ethics committees. J Med Ethics. 2007;33(5):294-301. [pmid: 17470508].
130 Wichman A, et al. Protecting human subjects in the NIH’s Intramural Research Program: a draft instrument to evaluate convened meetings of its IRBs. IRB. 2006;28(3):7-10. [pmid: 17036438].
131 Angell EL, et al. An analysis of decision letters by research ethics committees: the ethics/scientific quality boundary examined. Qual Saf Health Care. 2008;17(2):131-6. [pmid: 18385408].
132 Dixon-Woods M, et al. Written work: the social functions of Research Ethics Committee letters. Soc Sci Med. 2007;65(4):792-802. [pmid: 17490795].
133 MacNeil SD, Fernandez CV. Attitudes of research ethics board chairs towards disclosure of research results to participants: results of a national survey. J Med Ethics. 2007;33(9):549-53. [pmid: 17761827].
134 Macneil SD, Fernandez CV. Informing research participants of research results: analysis of Canadian university based research ethics board policies. J Med Ethics. 2006;32(1):49-54. [pmid: 16373524].
135 Vandenbrouke JP. More on the LIFE study. Lancet. 2003;261:532-3.
136 van der Meer JW, et al. Independent medical research. Neth J Med. 2007;65(4):124-6. [pmid: 17452759].
137 Kjaerdgard LL, Als-Nielson B. Association between competing interests and authors’ conclusions: epidemiological study of randomised clinical trials published in the BMJ. BMJ. 2002;325:24.
138 Lexchin J, et al. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ. 2003;326:1167-70. [pmid: 12775614].
139 Ridker PM, Torres J. Reported outcomes in major cardivascular clinical trials funded by for-profit and not-for-profit organizations. JAMA. 2006;295:2270-4. [pmid: 16705108].
140 Vandenbrouke JP. Was the LIFE trial independent?. Lancet. 2002;360:1171.
141 Choudry NK, Stelfox HT, Detsky AS. Relationships between authors of clinical practice guidelines and the pharmaceutical industry. JAMA. 2002;287:612-7. [pmid: 11829700].
142 Hall MA. The theory and practice of disclosing HMO physician incentives. Law Contemp Probl. 2002;64:207-40.