# INTRODUCTION

Ethical integrity in the conduct of health care research is essential for maintaining the public trust and support of such activities. Without research, health care cannot advance in a scientific fashion. But by definition, research that involves human participants necessitates that some aspects of their care are no longer being provided solely for their health benefit: research is meant to inform the care of future patients. Therefore, care provided as part of a research protocol always involves a risk of harm. Sometimes it is a direct health risk, as in the case of a new treatment of hoped-for-but-as-yet-unproven benefit with the potential for certain adverse events; or it may be less obvious, such as the risk of disclosure of sensitive information. The ethical management of risk is a primary focus of maintaining integrity in research.

Landmarks in the evolution of ethics for the conduct of research on humans include the 1946 Nuremberg code in response to atrocities committed by Nazi physicians on prisoners, which stated the basic requirement for any such research be “the voluntary consent” of the subjects involved;1 the Declaration of Helsinki (1964, with subsequent updates) that declared (among other things) that informed consent is necessary, that risks should not exceed benefits, and that research protocols should be reviewed by an independent committee;2 the exposé by Henry Beecher (1966) of about two dozen “unethical or questionable ethical studies;”3 and the Belmont Report (1979), which was undertaken in part as the result of the infamous Tuskegee Syphilis study, where curative treatment was withheld from low-income African American males with syphilis.4 The Belmont Report established the three basic principles of ethical research: respect for persons, beneficence, and justice; and their application to informed consent, assessment of risk and benefits, and the selection of subjects (participants).

In 1966, partly in response to the exposé by Beecher, the United States Public Health Service released a policy statement on ethical conduct of research:

“No new, renewal, or continuation research or research training grant in support of clinical research and investigation involving human beings shall be awarded by the Public Health Service unless the grantee has indicated in the application the manner in which the grantee institution will provide prior review of the judgment of the principal investigator or program director by a committee of his institutional associates.”5

And thus the Institutional Review Board (IRB) became a requirement for federally funded research.

## CURENT ISSUES INVOLVING INSTITUTIONAL REVIEW BOARDS

In today’s research environment, the IRB serves a number of functions, first and foremost being the protection of research participants. This protection includes insurance that potential participants are sufficiently briefed about the nature of the research and their participation that they are able to provide informed consent. The IRB also evaluates the appropriateness of payment for research participation and recruitment. IRBs set policies on the kinds of data that can be collected from participants, e.g., genetic profiles, and how those data must be protected. IRBs also distinguish what activities constitute a research study with human participation from quality improvement initiatives that do not directly involve participants. Researchers as well as IRBs grapple with how to ensure that research conducted at multiple sites or by investigators from multiple institutions adequately protects participants (which often requires review by an IRB at each site or institution). Finally, IRBs assess whether disclosure of potential financial conflicts of interest among research team members is required as part of the management plan when a conflict exists.

## CONFLICT OF INTEREST AND INSTITUTIONAL REVIEW BOARDS

The fact that money and reputations depend on the results of some research creates the potential for conflicts of interest (COI). Research investigators who have a financial or non-financial interest in the results of their research may consciously or unconsciously bias the conduct and interpretation of a study to yield their preferred outcome. The issue of COI in medical research has been the subject of countless lay media stories and numerous reports and commissions. One of the most prominent recent reports was from the Institute of Medicine: “Conflict of Interest in Medical Research, Education and Practice.” Two of the principle recommendations of the IOM report were as follows:

1. “Institutions that carry out medical research, medical education, clinical care, or practice guideline development should adopt, implement, and make public conflict of interest policies for individuals that are consistent with the other recommendations in this report. To manage identified conflicts of interest and monitor the implementation of management recommendations, institutions should create a conflict of interest committee. That committee should use a full range of management tools, as appropriate, including elimination of the conflicting financial interest, prohibition or restriction of involvement of the individual with a conflict of interest in the activity related to the conflict, and providing additional disclosures of the conflict of interest.” (p.18)
2. “The National Institutes of Health should develop rules governing institutional conflicts of interest for research institutions covered by current U.S. Public Health Service regulations. The rules should require the reporting of identified institutional conflicts of interest and the steps that have been taken to eliminate or manage such conflicts.”6 (p. 22)

The considerable potential for COI has been documented numerous times. In a systematic review by Bekelman and colleagues, 37 studies were identified that assessed the extent or impact of financial relationships between industry investigators, and academic institutions.7 Findings showed that 23 percent to 28 percent of academic investigators received research funding from industry and that many academic institutions had equity positions in start-up companies that sponsor research. Furthermore, industry sponsorship was significantly associated with conclusions favorable to the industry. Similar and more recent results were listed in the IOM report: For example, 27 percent of academic department chairs are paid consultants to industry.8 The report listed a number of particularly troubling examples of biased reporting in industry-supported clinical research. Also, studies have documented marked variability in the institutional policies regarding COI. In a 1998 survey of 100 leading research institutions in the United States, about half required disclosure by all faculty while another half required disclosure only from principle investigators or those conducting research.9 This analysis concluded that most policies on COI lack specificity about the kinds of relationships with industry that are permitted or prohibited. Studies have shown variability in how conflict of interest policies are implemented, even within a single university system.10, 11

The aim of this report was to catalog the literature on issues pertaining to IRBs and the ethical conduct of research, to identify the issue with the greatest number of published studies for which no current VA policy exists, and to assess the evidence regarding that issue, which was policies for minimizing conflict of interest and the activities of the IRB in that regard.