# EVIDENCE TABLES

Author/Year | Study Design | Participants | Findings
Lo, 2000^100^ | Analysis of COI policies | 10 US Medical Schools receiving the largest amount of research funding from the NIH: Baylor, Columbia, Harvard, Johns Hopkins, UCLA, UCSF, U. of Penn, U. of Washington, Washington U., Yale | - all policies required disclosure of financial interests, including stock and stock options and income from salary, honorariums and consulting fees.; - 5 required disclosure of all financial interest, regardless of the value; - 5 required disclosure if > $10,000; - Further info on person required to disclose, to whom to disclose, prohibited interests
McCrary, 2000^99^ | Deductive content analysis on COI policies to evaluate the documents according to certain domains | All US Medical Schools (n=127), and other research institutions (n=170) that received more than $5 million in total grants annually from the NIH or NHS, 48 journals in basic science and clinical medicine, and 17 federal agencies N= 250 institutions, 47 journals, 16 federal agencies | - 250 institutions:; 6% had no COI policies; 91% adhered to the federal threshold for disclosure, 9% exceeded federal guidelines; - Journals:; 43% had policies requiring disclosure of COI; - Federal agencies:; 25% had policies that explicitly addressed COI; 15/16-relied primarily on institutional discretion; - Further info on 235 institutions with disclosure requirements including: type of conflict, person (or entity) with interest requiring initial disclosure, party to which initial disclosure must be made, when disclosure is required, how disclosure should be managed, penalty for nondisclosure.
Weinfurt, 2010^13^ | Survey of financial conflict policies | 199 sites in US with at least partial commercial sponsorship that contributed participants to phase 3 clinical trials, the results of which were published in either JAMA or NEJM. Response rate/(n) = 66% (61) for academic medical centers, 37% (77) for non-academic medical centers, and 27% (61) for nonacademic outpatient settings | Compared academic medical centers/nonacademic medical centers/outpatient nonacademic sites in various domains, including: Follow formal written policy on investigator financial relationships- 97%/87%/44% Also, whether required to report financial relationships, type of IRB review, the persons or groups with role in review of investigators’ financial relationships, whether consideration of reasonableness of per capita payment amounts, whether institution has nonemployee investigators and reviews financial relationships of nonemployee investigators, whether institution uses monetary threshold below which there is no review of investigators/financial relationships, whether institution uses NIH threshold, and whether there are prohibited financial relationships.
Weinfurt, 2007^96^ | Focus groups, cognitive interviews and expert panel development and revision | 16 focus groups with healthy adults, adults with mild chronic/serious illness, parents of healthy/seriously ill children; cognitive interviews (n=10) with a convenience sample from primary care clinic; an expert panel discussion | - developed model disclosure statement. included generic disclosure statement (person leading study might benefit financially), specific disclosure statement (how might benefit financially- including descriptions of salary support, money received outside of the study, per capita payments, finders’ fees restricted to research uses, unrestricted finders’ fees, researcher or university holding a patent or equity
Weinfurt, 2006^92^ | Descriptive assessment of COI policies, most collected via publicly available information on internet | 123 academic medical centers, with IRBs. Response rate/(n) = 98% (120) | - goals of disclosure of COI should include: promoting autonomy, avoid legal liability, and deterrence.; - majority of policies most consistent with goal of avoiding legal liability.; - 48% mentioned disclosure to potential research subjects. Of these, 58% required or suggested verbatim language for the informed consent document.; - all required disclosure of the study sponsor, 38% required nature of financial relationship disclosed.; - 18% specified disclosing how funds allocated.; - 4% required notification that protocol reviewed by COIC or other administrative body.; - 5% made reference to nonfinancial interests.
Weinfurt, 2006^97^ | Scripted interviews | 10 US academic medical centers, 10 independent hospitals, 10 independent IRBs and 10 unaffiliated research entities N= 23 IRB chairs, 14 COIC chairs and 8 investigators | Coding of interview transcripts led to comparisons between investigators, IRB chairs and COIC chairs regarding circumstances in which conflicts of interest should be disclosed, rationale for or benefits of disclosure, information to be disclosed, negative effects or barriers to disclosure, timing of disclosure.
Campbell, 2006^93^ | Survey on financial relationships between IRB members and industry | Random sample of 893 IRB members at 100 academic institutions in US. Response Rate/(n), 67.2% (574) | 78 reported at least one protocol came before their IRB with which they had COI 58% always disclosed the relationship to an IRB official 8% sometimes did 12% rarely did 23% never did Of the 62 who were voting members 65% never voted on a protocol 5% rarely did 11% sometimes did 19% always did
Vogeli, 2009^95^ | Anonymous survey of IRB chairs | IRB chairs at the most research-intensive medical institutions in US Response Rate/(n) = 71.7% (211) | 68% have written policy defining COI 22% did not 9% did not know Further info on to whom to report, how disclosure managed, confidence in policies/procedures, how conflicts managed
Wolf, 2007^91^ | Assessment of IRB policies regarding COI, most collected from IRB websites and IRB representatives | 121 medical schools receiving NIH funding in fiscal year 2003 | 74% had written policies 79% of those defined what constituted a COI; - 10 required any financial interest disclosed; - 23 only > $10,000; - 4 significant (undefined) financial interests; - 14 no definition of a financial interest; 99% referred to all IRB members, 1% only IRB chairs, 14% IRB staff, 20% ad hoc reviewers and consultants, 4% guests 4/92 address failure to comply
Brody, 2003^98^ | Self-report questionnaire with 12 questions relating to policy for disclosure, institutional management of disclosed possible COIs, action by institution when COI is not disclosed | 158 senior investigators, 297 senior research administrators, 195 bioethicists, 17 journal editors and 7 agency administrators | Overall, all supported disclosure to IRBs, research subjects, journals and funding agencies Only the bioethicists were strongly supportive of including research subjects
Weinfurt, 2009^94^ | Examined 5 years of empirical data from the Conflict of Interest Notification study, to formulate 6 suggested goals of disclosure | n/a, data from study | 6 goals of disclosure: promoting informed decision making, respecting participants’ perceived right to know, establishing or maintaining trust, minimizing risk of legal liability, deterring troubling financial relationships, protecting research participants’ welfare