# References

1 Institute NE. Cataracts. https://www.nei.nih.gov/eyedata/cataract.
2 Hedges LV, Vevea JL. Fixed-and random-effects models in meta-analysis. Psychological methods. 1998;3(4):486.
3 Konstantopoulos S. Fixed effects and variance components estimation in three-level meta-analysis. Res Synth Methods. 2011;2(1):61-76.26061600
4 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560.12958120
5 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-1101.7786990
6 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-634.9310563
7 Gedde SJ, Herndon LW, Brandt JD, Budenz DL, Feuer WJ, Schiffman JC. Postoperative complications in the Tube Versus Trabeculectomy (TVT) study during five years of follow-up. American journal of ophthalmology. 2012;153(5):804-814.e801.22244522
8 Wilkins MR, Allan BD, Rubin GS, et al. Randomized trial of multifocal intraocular lenses versus monovision after bilateral cataract surgery. Ophthalmology. 2013;120(12):2449-2455 e2441.24070808
9 Alio JL, Grabner G, Plaza-Puche AB, et al. Postoperative bilateral reading performance with 4 intraocular lens models: six-month results. Journal of cataract and refractive surgery. 2011;37(5):842-852.21511152
10 Marchini G, Mora P, Pedrotti E, Manzotti F, Aldigeri R, Gandolfi SA. Functional assessment of two different accommodative intraocular lenses compared with a monofocal intraocular lens. Ophthalmology. 2007;114(11):2038-2043.17555820
11 Zeng M, Liu Y, Liu X, et al. Aberration and contrast sensitivity comparison of aspherical and monofocal and multifocal intraocular lens eyes. Clinical & experimental ophthalmology. 2007;35(4):355-360.17539788
12 Ji J, Huang X, Fan X, Luo M. Visual performance of Acrysof ReSTOR compared with a monofocal intraocular lens following implantation in cataract surgery. Exp Ther Med. 2013;5(1):277-281.23251283
13 Peng C, Zhao J, Ma L, Qu B, Sun Q, Zhang J. Optical performance after bilateral implantation of apodized aspheric diffractive multifocal intraocular lenses with +3.00-D addition power. Acta ophthalmologica. 2012;90(8):e586-593.23194310
14 Zhao G, Zhang J, Zhou Y, Hu L, Che C, Jiang N. Visual function after monocular implantation of apodized diffractive multifocal or single-piece monofocal intraocular lens Randomized prospective comparison. Journal of cataract and refractive surgery. 2010;36(2):282-285.20152611
15 Cillino S, Casuccio A, Di Pace F, et al. One-year outcomes with new-generation multifocal intraocular lenses. Ophthalmology. 2008;115(9):1508-1516.18538402
16 Alio JL, Plaza-Puche AB, Pinero DP, Amparo F, Rodriguez-Prats JL, Ayala MJ. Quality of life evaluation after implantation of 2 multifocal intraocular lens models and a monofocal model. Journal of cataract and refractive surgery. 2011;37(4):638-648.21420587
17 Labiris G, Giarmoukakis A, Patsiamanidi M, Papadopoulos Z, Kozobolis VP. Mini-monovision versus multifocal intraocular lens implantation. Journal of cataract and refractive surgery. 2015;41(1):53-57.24962144
18 Martinez Palmer A, Gomez Faina P, Espana Albelda A, Comas Serrano M, Nahra Saad D, Castilla Cespedes M. Visual function with bilateral implantation of monofocal and multifocal intraocular lenses: a prospective, randomized, controlled clinical trial. Journal of refractive surgery (Thorofare, NJ: 1995). 2008;24(3):257-264.
19 Rasp M, Bachernegg A, Seyeddain O, et al. Bilateral reading performance of 4 multifocal intraocular lens models and a monofocal intraocular lens under bright lighting conditions. Journal of cataract and refractive surgery. 2012;38(11):1950-1961.23079311
20 Menant JC, St George RJ, Sandery B, Fitzpatrick RC, Lord SR. Older people contact more obstacles when wearing multifocal glasses and performing a secondary visual task. Journal of the American Geriatrics Society. 2009;57(10):1833-1838.19694864
21 Braga-Mele R, Chang D, Dewey S, et al. Multifocal intraocular lenses: relative indications and contraindications for implantation. Journal of cataract and refractive surgery. 2014;40(2):313-322.24461503