# Abstract

## Introduction

The comparative effectiveness of multifocal, accommodative, and monofocal intraocular lenses for cataract surgery and lens replacement remains unclear. This review was requested to assess the evidence.

### Key Questions

1. What is the effectiveness of multifocal or accommodative versus monofocal lenses with spectacle correction for distance vision in the setting of cataract surgery?

2. What is the effectiveness of multifocal or accommodative versus monofocal lenses with spectacle correction for near vision in the setting of cataract surgery?

3. What are the harms associated with multifocal or accommodative lenses versus monofocal replacement in the setting of cataract surgery?

4. If feasible, what resources are required to best care for patients who choose multifocal or accommodative lens implants in the setting of cataract surgery?

## Methods

### Data Sources and Searches

We conducted searches in PubMed from 1/1/2006 to 4/30/2017.

### Study Selection

Studies were included if they were randomized trials of a US FDA-approved lens that was either multifocal or accommodative and compared to standard monofocal IOLs (or monovision) in the setting of adult cataract extraction and reported visual acuity outcomes, spectacle independence, or visual function/quality of life.

### Data Synthesis and Analysis

Data extraction was completed in duplicate, and included: study design, single versus multi-site study, patient characteristics, intervention lenses, comparison monofocal lens, sample size, duration of follow-up, outcomes, and data needed for the Cochrane Risk of Bias tool.

## Results

### Results of Literature Search

Our literature searches and reference mining identified 760 potentially relevant citations, of which 93 abstracts were included and obtained as full-text publications. Twelve publications provided some insight into the comparative effectiveness of multifocal, accommodative, and monofocal intraocular lenses for cataract surgery and lens replacement, and are included in our final sample.

### Summary of Results for Key Questions

#### Key Question 1

The evidence from 9 RCTs supports a conclusion that there is no difference in uncorrected or corrected distance vision between multifocal or accommodative IOLs and monofocal IOLs. The evidence for accommodative IOLs is restricted to only 1 trial. Two trials comparing multifocal IOLs to monovision found no difference in uncorrected distance vision.

#### Key Question 2

Four RCTs support the conclusion that multifocal IOLs are better than monofocal IOLs for uncorrected near vision. This conclusion is also supported by better outcomes for reading accuracy, reading speed, and visual function. In the few studies that have measured visual function or vision-related quality of life, this has been better in patients receiving multifocal IOLs. Data on accommodative IOLs are very sparse. The 2 studies comparing multifocal IOLs to monovision found that multifocal IOLs result in better spectacle independence than monovision.

#### Key Question 3

Between 3 and 8 RCTs support the following conclusions: 1) The risks of surgery are no greater for multifocal IOLs than monofocal IOLs in the patient population and lenses included in these trials; 2) Multifocal IOLs may have an increased risk of IOL exchange due to patient dissatisfaction; 3) Multifocal IOLs are associated with worse contrast sensitivity; 4) Multifocal IOLs are associated with greater risk of glare; 5) Multifocal IOLs are associated with a greater risk of halos; 6) Data on accommodative IOLs are too sparse to draw conclusions.

#### Key Question 4

No hypothesis-testing study explicitly assessed the need for additional pre-operative or post-operative resources for patients receiving multifocal IOLs. However, several of the included trials used, as exclusion criteria, conditions that would require additional diagnostic tests that may go beyond the standard pre-operative evaluation for monofocal IOLs. Specialty society “best practice” recommendations for multifocal IOL procedures list a number of pre-operative and post-operative best practices that may not be included as part of standard monofocalIOL procedures.

## Discussion

### Key Findings and Strength of Evidence

Moderate-strength evidence supports the conclusion that, compared to monofocal IOLs, multifocal IOLs achieve better outcomes on spectacle independence and uncorrected near visual acuity, without sacrificing uncorrected or corrected distance vision. Low-strength evidence supports the conclusion that multifocal IOLs result in better visual function/ quality of life than monofocal IOLs. More limited data support that multifocal IOLs achieve better spectacle independence than monovision. Moderate-strength evidence supports that multifocal IOLs result in worse contrast sensitivity and a greater risk of glare, and low-strength evidence supports that they result in a greater risk of halos. Low strength evidence exists that monofocal IOLs result in greater IOL exchange due to dissatisfaction. Data are very limited about accommodative IOLs, consisting of only 1 RCT.

### Applicability

No studies were performed in VA populations, or even US populations; therefore, the applicability of these results to VA patients with cataracts is uncertain. A limitation is that IOL technology is rapidly changing, and therefore newer lenses may have differences in the benefits and harms we report here for older lenses.

## Research Gaps/Future Research

A VA-sponsored multi-site randomized clinical trial would provide higher quality evidence than what currently exists about the benefits, harms, needed pre- and post-operative resources, and costs of multifocal IOLs compared to monofocal IOLs.

## Conclusions

Multifocal IOLs compared to monofocal IOLs produce better uncorrected near vision and a greater proportion of patients who are spectacle independent, but are associated with worse contrast sensitivity and a greater risk of glare and halos. Current evidence is insufficient to reach conclusions about resource requirements and other outcomes such as additional enhancements or IOL exchange.

## Abbreviations

AA: Accommodative amplitude
ACD: Anterior chamber depth
BCDVA: Best corrected distance visual acuity
BCIVA: Best corrected intermediate visual acuity
BCNVA: Best corrected near visual acuity
BCVA: Best corrected visual acuity
CDVA: Corrected distance visual acuity
CPD6: 6 cycles per degree
DCNVA: Distance-corrected near visual acuity
GRADE: Grading of Recommendations Assessment, Development and Evaluation
IOL: Intraocular Cataract Lenses
LASIK: Laser-assisted in situ keratomileusis
logMAR: Logarithm of the Minimum Angle of Resolution
MD: Mean Difference
MFIOL: Multifocal Intraocular Lens
MTF: Modulation transfer function
NDRA: Near-distance refractive addition
NVA: Near visual acuity
RMS: Root mean square
RMS4: Root mean square four
RMSh: RMS high order
RR: Risk Ratio
SCPA: Sclerociliary process angle
SMD: Standardized effective size
TEP: Technical Expert Panel
UCNVA: Uncorrected near visual acuity
UDVA: Uncorrected distance visual acuity
UIVA: Uncorrected intermediate visual acuity
UNVA: Uncorrected near visual acuity
VF7: Visual function index (shortened)
VF11R: Rasch-modified National Eye Institute Visual Function questionnaire
VF14: Visual function index