# APPENDIX E Results of Pooled Analyses Comparing Multifocal IOLS with Monovision

Figure 1 Multifocal IOLs Compared to Monovision Uncorrected Distance

Figure 2 Multifocal IOLs Compared to Monovision Uncorrected Near

Figure 3 Multifocal IOLs Compared to Monovision Quality of Life

Figure 4 Multifocal IOLs Compared to Monovision Spectacle Independence