# APPENDIX D Citations for Excluded Studies

Lens not of interest (n=30)

1 Alio JL, Plaza-Puche AB, Pinero DP. Rotationally asymmetric multifocal IOL implantation with and without capsular tension ring: refractive and visual outcomes and intraocular optical performance. Journal of refractive surgery (Thorofare, NJ: 1995). 2012;28(4):253-258.
2 Alio JL, Simonov A, Plaza-Puche AB, et al. Visual Outcomes and Accommodative Response of the Lumina Accommodative Intraocular Lens. American journal of ophthalmology. 2016;164:37-48.26829595
3 Allen ED, Burton RL, Webber SK, et al. Comparison of a diffractive bifocal and a monofocal intraocular lens. Journal of cataract and refractive surgery. 1996;22(4):446-451.8733848
4 Bournas P, Drazinos S, Kanellas D, Arvanitis M, Vaikoussis E. Dysphotopsia after cataract surgery: comparison of four different intraocular lenses. Ophthalmologica Journal international d’ophtalmologie International journal of ophthalmology Zeitschrift fur Augenheilkunde. 2007;221(6):378-383.
5 Cleary G, Spalton DJ, Gala KB. A randomized intraindividual comparison of the accommodative performance of the bag-in-the-lens intraocular lens in presbyopic eyes. American journal of ophthalmology. 2010;150(5):619-627.e611.20719298
6 el-Maghraby A, Marzouky A, Gazayerli E, Van der Karr M, DeLuca M. Multifocal versus monofocal intraocular lenses. Visual and refractive comparisons. Journal of cataract and refractive surgery. 1992;18(2):147-152.1564652
7 Haaskjold E, Allen ED, Burton RL, et al. Contrast sensitivity after implantation of diffractive bifocal and monofocal intraocular lenses. Journal of cataract and refractive surgery. 1998;24(5):653-658.9610448
8 Hancox J, Spalton D, Heatley C, Jayaram H, Marshall J. Objective measurement of intraocular lens movement and dioptric change with a focus shift accommodating intraocular lens. Journal of cataract and refractive surgery. 2006;32(7):1098-1103. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/953/CN-00612953/frame.html.16857494
9 Hancox J, Spalton D, Heatley C, et al. Fellow-eye comparison of posterior capsule opacification rates after implantation of 1CU accommodating and AcrySof MA30 monofocal intraocular lenses. Journal of cataract and refractive surgery. 2007;33(3):413-417.17321391
10 Harman FE, Maling S, Kampougeris G, et al. Comparing the 1CU accommodative, multifocal, and monofocal intraocular lenses: a randomized trial. Ophthalmology. 2008;115(6):993-1001 e1002.18031818
11 Henriquez M, lzquierdo L, Mendoza AJ, Suarez P. Comparison of Visual Results in Monofocal (Clariflex) vs. Multifocal (ReZoom) IOLs After Cataract Surgery. American Academy of Ophthalmology. 2006:201. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/822/CN-00634822/frame.html.
12 Javitt J, Brauweiler HP, Jacobi KW, et al. Cataract extraction with multifocal intraocular lens implantation: clinical, functional, and quality-of-life outcomes. Multicenter clinical trial in Germany and Austria. Journal of cataract and refractive surgery. 2000;26(9):1356-1366.11020621
13 Javitt JC, Steinert RF. Cataract extraction with multifocal intraocular lens implantation: a multinational clinical trial evaluating clinical, functional, and quality-of-life outcomes. Ophthalmology. 2000;107(11):2040-2048.11054329
14 Joshi RS. Diffractive multifocal intraocular lens compared to pseudo-accommodative intraocular lens implant for unilateral cataracts in pre-presbyopic patients. Middle East African journal of ophthalmology. 2013;20(3):207-211.24014982
15 Jusufovic V, Sarajlic D, Zvornicanin J, Musanovic Z, Halilbasic M. Comparison of the binocular vision quality after implantation of monofocal and multifocal intraocular lenses. Acta Medica Saliniana. 2011;40(2):63-68. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/693/CN-00897693/frame.html.
16 Kamlesh, Dadeya S, Kaushik S. Contrast sensitivity and depth of focus with aspheric multifocal versus conventional monofocal intraocular lens. Canadian journal of ophthalmology Journal canadien d’ophtalmologie. 2001;36(4):197-201.
17 Kaya V, Ozturker ZK, Ozturker C, et al. ThinOptX vs AcrySof: comparison of visual and refractive results, contrast sensitivity, and the incidence of posterior capsule opacification. European journal of ophthalmology. 2007;17(3):307-314.17534808
18 Kretz F, Gerl M, Gerl R, Müller M, Auffarth G. Clinical evaluation of a new pupil independent diffractive multifocal intraocular lens with a +2.75 D near addition: a European multicentre study. British journal of ophthalmology. 2017;99(12):1655-1659. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/166/CN-01258166/frame.html.
19 Lau G, Kasthurirangan S, Vargas L. Functional vision with diffractive multifocal and accommodating iols. American Academy of Optometry. 2009. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/688/CN-00745688/frame.html.
20 Leyland MD, Langan L, Goolfee F, Lee N, Bloom PA. Prospective randomised double-masked trial of bilateral multifocal, bifocal or monofocal intraocular lenses. Eye (London, England). 2002;16(4):481-490.
21 Maxwell W, Waycaster C, D’Souza A, Meissner B, Hileman K. A United States cost-benefit comparison of an apodized, diffractive, presbyopia-correcting, multifocal intraocular lens and a conventional monofocal lens. Journal of cataract and refractive surgery. 2008;34(11):1855-1861. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/351/CN-00665351/frame.html.19006730
22 Mojzis P, Kukuckova L, Majerova K, Liehneova K, Pinero DP. Comparative analysis of the visual performance after cataract surgery with implantation of a bifocal or trifocal diffractive IOL. Journal of refractive surgery (Thorofare, NJ: 1995). 2014;30(10):666-672.
23 Nijkamp MD, Dolders MG, de Brabander J, van den Borne B, Hendrikse F, Nuijts RM. Effectiveness of multifocal intraocular lenses to correct presbyopia after cataract surgery: a randomized controlled trial. Ophthalmology. 2004;111(10):1832-1839.15465543
24 Percival SS, SS. Prospectively randomized trial comparing the pseudoaccommodation of the AMO ARRAY multifocal lens and a monofocal lens. Journal of cataract and refractive surgery. 1993;19(1):26-31.8426316
25 Rossetti L, Carraro F, Rovati M, Orzalesi N. Performance of diffractive multifocal intraocular lenses in extracapsular cataract surgery. Journal of cataract and refractive surgery. 1994;20(2):124-128.8201559
26 Sen HN, Sarikkola AU, Uusitalo RJ, Laatikainen L. Quality of vision after AMO Array multifocal intraocular lens implantation. Journal of cataract and refractive surgery. 2004;30(12):2483-2493.15617914
27 Steinert RF, Post CT, Jr., Brint SF, et al. A prospective, randomized, double-masked comparison of a zonal-progressive multifocal intraocular lens and a monofocal intraocular lens. Ophthalmology. 1992;99(6):853-860; discussion 860-851.1630773
28 Tang W, Zhuang S, Liu G. Comparison of visual function after multifocal and accommodative IOL implantation. Eye science. 2014;29(2):95-99.26011959
29 Wang M, Corpuz C, Fujiwara M, Tomita M. Visual and optical performance of diffractive multifocal intraocular lenses with different haptic designs: 6 month follow-up. Clinical ophthalmology (Auckland, NZ). 2014;8:919-926. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/876/CN-00992876/frame.html.
30 Wolffsohn JS, Naroo SA, Motwani NK, et al. Subjective and objective performance of the Lenstec KH-3500 "accommodative" intraocular lens. The British journal of ophthalmology. 2006;90(6):693-696.16531421

No monofocal comparison (n=21)

31 Alfonso JF, Fernandez-Vega L, Puchades C, Montes-Mico R. Intermediate visual function with different multifocal intraocular lens models. Journal of cataract and refractive surgery. 2010;36(5):733-739.20457363
32 Barisic A, Dekaris I, Gabric N, et al. Comparison of diffractive and refractive multifocal intraocular lenses in presbyopia treatment. Collegium antropologicum. 2008;32 Suppl 2:27-31.
33 Bijaoui S, Milazzo S, Thomas F, Berthout A. Comparison of Visual Results and Quality of Vision Between Two Multifocal Intra Ocular Lenses: Rezoom versus ReSTOR. Iovs. 2007;48:ARVO E-Abstract 3122. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/159/CN-00746159/frame.html.
34 Chiam PJ, Chan JH, Haider SI, Karia N, Kasaby H, Aggarwal RK. Functional vision with bilateral ReZoom and ReSTOR intraocular lenses 6 months after cataract surgery. Journal of cataract and refractive surgery. 2007;33(12):2057-2061. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/622/CN-00717622/frame.html.18053904
35 Gangwani V, Hirnschall N, Findl O, Maurino V. Multifocal toric intraocular lenses versus multifocal intraocular lenses combined with peripheral corneal relaxing incisions to correct moderate astigmatism. Journal of cataract and refractive surgery. 2014;40(10):1625-1632.25263038
36 Gil MA, Varon C, Rosello N, Cardona G, Buil JA. Visual acuity, contrast sensitivity, subjective quality of vision, and quality of life with 4 different multifocal IOLs. European journal of ophthalmology. 2012;22(2):175-187.21623590
37 Hutz WW, Eckhardt HB, Rohrig B, Grolmus R. Intermediate vision and reading speed with array, Tecnis, and ReSTOR intraocular lenses. Journal of refractive surgery (Thorofare, NJ: 1995). 2008;24(3):251-256.
38 Hutz WW, Jackel R, Hoffman PC. Comparison of visual performance of silicone and acrylic multifocal IOLs utilizing the same diffractive design. Acta ophthalmologica. 2012;90(6):530-533.20716324
39 Jonker SM, Bauer NJ, Makhotkina NY, Berendschot TT, van den Biggelaar FJ, Nuijts RM. Comparison of a trifocal intraocular lens with a +3.0 D bifocal IOL: results of a prospective randomized clinical trial. Journal of cataract and refractive surgery. 2015;41(8):1631-1640.26432120
40 Lane SS, Javitt JC, Nethery DA, Waycaster C. Improvements in patient-reported outcomes and visual acuity after bilateral implantation of multifocal intraocular lenses with +3.0 diopter addition: multicenter clinical trial. Journal of cataract and refractive surgery. 2010;36(11):1887-1896.21029897
41 Leydolt C, Neumayer T, Prinz A, Findl O. Effect of patient motivation on near vision in pseudophakic patients. American journal of ophthalmology. 2009;147(3):398-405.e393.19019338
42 Mastropasqua R, Toto L, Vecchiarino L, Falconio G, Nicola MD, Mastropasqua A. Multifocal IOL implant with or without capsular tension ring: study of wavefront error and visual performance. European journal of ophthalmology. 2013;23(4):510-517.23516249
43 Maurino V, Allan BD, Rubin GS, Bunce C, Xing W, Findl O. Quality of vision after bilateral multifocal intraocular lens implantation: a randomized trial--AT LISA 809M versus AcrySof ReSTOR SN6AD1. Ophthalmology. 2015;122(4):700-710.25537197
44 Maxwell WA, Cionni RJ, Lehmann RP, Modi SS. Functional outcomes after bilateral implantation of apodized diffractive aspheric acrylic intraocular lenses with a +3.0 or +4.0 diopter addition power Randomized multicenter clinical study. Journal of cataract and refractive surgery. 2009;35(12):2054-2061.19969208
45 Munoz G, Albarran-Diego C, Javaloy J, Sakla HF, Cervino A. Combining zonal refractive and diffractive aspheric multifocal intraocular lenses. Journal of refractive surgery (Thorofare, NJ: 1995). 2012;28(3):174-181.
46 Nuijts RM, Jonker SM, Kaufer RA, et al. Bilateral implantation of +2.5 D multifocal intraocular lens and contralateral implantation of +2.5 D and +3.0 D multifocal intraocular lenses: Clinical outcomes. Journal of cataract and refractive surgery. 2016;42(2):194-202.27026442
47 Pepose JS, Hayashida J, Hovanesian J, et al. Safety and effectiveness of a new toric presbyopia-correcting posterior chamber silicone intraocular lens. Journal of cataract and refractive surgery. 2015;41(2):295-305.25661122
48 Santhiago MR, Netto MV, Espindola RF, et al. Comparison of reading performance after bilateral implantation of multifocal intraocular lenses with +3.00 or +4.00 diopter addition. Journal of cataract and refractive surgery. 2010;36(11):1874-1879.21029895
49 Santhiago MR, Wilson SE, Netto MV, et al. Visual performance of an apodized diffractive multifocal intraocular lens with +3.00-d addition: 1-year follow-up. Journal of refractive surgery (Thorofare, NJ: 1995). 2011;27(12):899-906.
50 Santhiago MR, Wilson SE, Netto MV, et al. Modulation transfer function and optical quality after bilateral implantation of a +3.00 D versus a +4.00 D multifocal intraocular lens. Journal of cataract and refractive surgery. 2012;38(2):215-220.22104642
51 Toto L, Falconio G, Vecchiarino L, et al. Visual performance and biocompatibility of 2 multifocal diffractive IOLs: six-month comparative study. Journal of cataract and refractive surgery. 2007;33(8):1419-1425. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/662/CN-00717662/frame.html.17662435

Not intervention of interest (n=9)

52 Alio JL, Plaza-Puche AB, Javaloy J, Ayala MJ, Vega-Estrada A. Clinical and optical intraocular performance of rotationally asymmetric multifocal IOL plate-haptic design versus C-loop haptic design. Journal of refractive surgery (Thorofare, NJ: 1995). 2013;29(4):252-259.
53 Barisic A, Gabric N, Dekaris I, Romac I, Bohac M, Juric B. Comparison of different presbyopia treatments: refractive lens exchange with multifocal intraocular lens implantation versus LASIK monovision. Collegium antropologicum. 2010;34 Suppl 2:95-98.
54 Donnenfeld E, Roberts C, Perry H, Solomon R, Wittpenn J, McDonald M. Efficacy of Topical Cyclosporine versus Tears for Improving Visual Outcomes Following Multifocal IOL Implantation. Iovs. 2007;48:ARVO E-Abstract 1066. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/705/CN-00745705/frame.html.
55 Donnenfeld ED, Solomon R, Roberts CW, Wittpenn JR, McDonald MB, Perry HD. Cyclosporine 0.05% to improve visual outcomes after multifocal intraocular lens implantation. Journal of cataract and refractive surgery. 2010;36(7):1095-1100.20610085
56 Fernandez-Vega L, Madrid-Costa D, Alfonso JF, Montes-Mico R, Poo-Lopez A. Optical and visual performance of diffractive intraocular lens implantation after myopic laser in situ keratomileusis. Journal of cataract and refractive surgery. 2009;35(5):825-832.19393880
57 Gerten G, Kermani O, Schmiedt K, Farvili E, Foerster A, Oberheide U. Dual intraocular lens implantation: Monofocal lens in the bag and additional diffractive multifocal lens in the sulcus. Journal of cataract and refractive surgery. 2009;35(12):2136-2143.19969220
58 Schrecker J, Feith A, Langenbucher A. Comparison of additional pseudophakic multifocal lenses and multifocal intraocular lens in the capsular bag. The British journal of ophthalmology. 2014;98(7):915-919.24554737
59 Schrecker J, Langenbucher A. Visual performance in the long term with secondary add-on versus primary capsular bag multifocal intraocular lenses. Journal of refractive surgery (thorofare, NJ: 1995). 2017;32(11):742-747. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/178/CN-01292178/frame.html.
60 Szigeti A, Kranitz K, Takacs AI, Mihaltz K, Knorz MC, Nagy ZZ. Comparison of long-term visual outcome and IOL position with a single-optic accommodating IOL After 5.5-or 6.0-mm Femtosecond laser capsulotomy. Journal of refractive surgery (Thorofare, NJ: 1995). 2012;28(9):609-613.

Not outcome of interest (n=2)

61 Dolders M, Nijkamp M, Nuijts R, et al. Cost effectiveness of foldable multifocal intraocular lenses compared to foldable monofocal intraocular lenses for cataract surgery. British journal of ophthalmology. 2004;88(9):1163-1168. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/359/CN-00480359/frame.html.15317709
62 Varon C, Gil MA, Alba-Bueno F, et al. Stereo-acuity in patients implanted with multifocal intraocular lenses: is the choice of stereotest relevant? Current eye research. 2014;39(7):711-719.24400719

Not RCT (n=16)

63 Visual performance and rotational stability of a multifocal toric intraocular lens. Journal of Refractive Surgery 32 (7) (pp 444-450), 2016 Date of Publication: July 2016. 2016. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/299/CN-01197299/frame.html.
64 Alfonso J, Puchades C, Fernandez-Vega L, Montes-Mico R, Valcarcel B, Ferrer-Blasco T. Visual acuity comparison of 2 models of bifocal aspheric intraocular lenses. Journal of cataract and refractive surgery. 2009;35(4):672-676. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/810/CN-00754810/frame.html.19304087
65 Bi H, Cui Y, Ma X, et al. Early clinical evaluation of AcrySof ReSTOR multifocal intraocular lens for treatment of cataract. Ophthalmologica Journal international d’ophtalmologie International journal of ophthalmology Zeitschrift für Augenheilkunde. 2008;222(1):11-16. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/916/CN-00621916/frame.html.
66 Chen T, Yu F, Lin H, et al. Objective and subjective visual quality after implantation of all optic zone diffractive multifocal intraocular lenses: a prospective, case-control observational study. British journal of ophthalmology. 2017;100(11):1530-1535. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/266/CN-01292266/frame.html.
67 Greenbaum S. Re: Wilkins et al.: randomized trial of multifocal intraocular lenses versus monovision after bilateral cataract surgery (Ophthalmology 2013;120:2449-55). Ophthalmology. 2014;121(7):e34. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/707/CN-01071707/frame.html.
68 Hantera M, Hamed A, Fekry Y, Shoheib E. Initial experience with an accommodating intraocular lens: controlled prospective study. Journal of cataract and refractive surgery. 2010;36(7):1167-1172. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/270/CN-00749270/frame.html.20610096
69 Knorz MC, Rincon JL, Suarez E, et al. Subjective outcomes after bilateral implantation of an apodized diffractive +3.0 D multifocal toric IOL in a prospective clinical study. Journal of refractive surgery (Thorofare, NJ: 1995). 2013;29(11):762-767.
70 Lawless M, Bali S, Hodge C, Roberts T, Chan C, Sutton G. Outcomes of femtosecond laser cataract surgery with a diffractive multifocal intraocular lens. Journal of refractive surgery (Thorofare, NJ: 1995). 2012;28(12):859-864. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/599/CN-00917599/frame.html.
71 Macsai MS, Padnick-Silver L, Fontes BM. Visual outcomes after accommodating intraocular lens implantation. Journal of cataract and refractive surgery. 2006;32(4):628-633.16698485
72 Patel S, Alio JL, Feinbaum C. Comparison of Acri. Smart multifocal IOL, crystalens AT-45 accommodative IOL, and Technovision presbyLASIK for correcting presbyopia. Journal of refractive surgery (Thorofare, NJ: 1995). 2008;24(3):294-299.
73 Pedrotti E, Mastropasqua R, Passilongo M, Parisi G, Marchesoni I, Marchini G. Comparison of two multifocal intraocular lens designs that differ only in near add. Journal of refractive surgery (Thorofare, NJ: 1995). 2014;30(11):754-760. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/711/CN-01036711/frame.html.
74 Perea-Milla E, Vidal S, Briones E, et al. Development and validation of clinical scores for visual outcomes after cataract surgery. Ophthalmology. 2011;118(1):9-16.e11-13.20723994
75 Sun Y, Zheng D, Song T, Liu Y. Visual function after bilateral implantation of apodized diffractive multifocal IOL with a +3.0 or +4.0 D addition. Ophthalmic Surgery Lasers and Imaging. 2011;42(4):302-307. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/105/CN-00890105/frame.html.
76 Vilupuru S, Lin L, Pepose JS. Comparison of Contrast Sensitivity and Through Focus in Small-Aperture Inlay, Accommodating Intraocular Lens, or Multifocal Intraocular Lens Subjects. American journal of ophthalmology. 2015;160(1):150-162.e151.25896457
77 Wang Q, Zhao G, Wang Q, Jia W. Visual quality after AcrySof IQ ReSTOR intraocular lens implantation in eyes with high myopia. European journal of ophthalmology. 2012;22(2):168-174. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/578/CN-00972578/frame.html.21607928
78 Zhang F, Sugar A, Jacobsen G, Collins M. Visual function and patient satisfaction: Comparison between bilateral diffractive multifocal intraocular lenses and monovision pseudophakia. Journal of cataract and refractive surgery. 2011;37(3):446-453. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/916/CN-00891916/frame.html.21333868

Background (n=1)

79 Silva S, Evans J, Kirthi V, Ziaei M, Leyland M. Multifocal versus monofocal intraocular lenses after cataract extraction. Cochrane database of systematic reviews (online). 2017;2016(12) (no pagination). http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/631/CN-01286631/frame.html.

Commentary (n=1)

80 Lloyd J. A randomized intraindividual comparison of the accommodative performance of the bag-in-the-lens intraocular lens in presbyopic eyes. Evidence-Based Ophthalmology. 2011;12(2):69-71. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/061/CN-00895061/frame.html.

Duplicate (n=1)

81 Joshi R. Diffractive multifocal intraocular lens compared to pseudo-Accommodative antraocular lens implant for unilateral cataracts in pre-Presbyopic patients. Middle East African journal of ophthalmology. 2013;20(3):207-211. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/028/CN-00911028/frame.html.24014982