# APPENDIX B Peer Review Comments/Author Responses

Comment | Response
Conclusions too favorable given all problems with studies on multifocal IOLs. | We have somewhat reduced the favorability.
Page 20 line 48 "independence" is spelled wrong Page 20 line 53 should be "than" not "that" page 29 Line 17 Summary # 1. I don’t think you can say the risk of surgery with multifocals is no greater as the undesirable visual issues post- operative-(glare, halos, decreased contrast) are uncorrectable and there is likely an increased risk of need for lens exchange which is a risky procedure. Do the authors mean the intraoperative risk is no greater? Page 32 lines 40-44: As far as the statement "there is no data to support complications or effectiveness of cataract surgery varies by population characteristics". This statement is likely not true. We do know certain characteristics and ocular co-morbidities increase the risk of undesirable visual outcomes (glare, halos, decreased contrast) with multifocals. This would then logically increase the risk of lens exchange and unfavorable visual outcomes. We would need to know what the prevalence of these characteristics such as dry eye and macular changes are in the VA population getting cataract surgery compared to the general population getting cataract surgery. Page 32 line 53-57 Conclusions: I would add the need for additional patient face-to-face or "chair" time and therefore resources and the higher need for lens exchange | Thank you for pointing this out, this has been corrected. Thank you for pointing this out, this has been corrected. The reviewer is correct, we meant interoperative risks. We have made this change. We changed this statement to saying the applicability is uncertain We made this addition.
This is well written summary of the literature. Unfortunately much of the literature was excluded to answer if multifocal lenses are more effective than monofocal lenses after implantation. I feel the authors made valid conclusions with the limited articles that met criteria for review. | Thank you for your comment.
My primary concern: there should be more of an emphasis in the poor quality of the studies (see page 13—e.g., only two were registered prospectively!), in the Discussion and Conclusions (pages 5-6). In this context, for example, "moderate evidence supports...." is overly optimistic. I really think more rigorous studies need to be done to support these IOLs (though this question is probably irrelevant given the significant financial incentives to use them outside the VA) and they should be in US populations (none of the studies in the ESP were done in the US, which I found very surprising and very disheartening). My opinion: much more caution needs to be emphasized in the report! Another concern: the ESP states that the findings are generalizable to the VA population (top of page 6). Given that none of the studies were done in US populations and that VA patients undergoing cataract surgery have much higher burden of illness that their non-VA counterparts in the US, I find this conclusion problematic. We simply do not know. | We have somewhat reduced our conclusions, in terms of applicability and potential for harms, but believe the assessment of quality of evidence as "moderate" for the conclusion that multifocal IOL, produce better uncorrected near vision and spectacle independence is justified. The methodologic limitations of the RCTs are already accounted for in the downgrade of the quality of evidence from high to moderate. This change was already made.
This was a very sound study that examined the outcomes of multifocal and accommodating IOL implantation relative to monofocal IOL implantation in cataract surgery. The methods of paper selection and the key investigational questions were clearly laid out. The statistical methods that were employed were appropriate. Given the data presented, I agree with the conclusions that were drawn with respect to the key questions. The results of the stringent screening process for the included papers highlights the deficiencies in the current literature and the challenges that present themselves when trying to design studies that answer the questions of interest. A weakness of the study (which is beyond the authors’ control) is the selection of IOLs that were available for examination in published randomized clinical trials. A few of the IOLs are not available in the US (Acri LISA, TwinSet) or are outdated technology not in current use (Array, ReZoom). Of the remaining IOLs (ReSTOR SN6AD3, Tenis ZM900/9001, Tecnis ZMB00), their use is being significantly replace by "lower-add" MFIOLs or extended depth-of-focus IOLs. The newer IOLs may have improved side effect profiles, but unfortunately the available literature is not of sufficient quality for a similar evaluation of their performance. Maybe mention could be made of these issues in the discussion and/or conclusion, if the authors feel it is appropriate. In today’s environment, I would be careful with the statement that corneal topography is not needed for "standard" cataract surgery. I believe the consensus that corneal topography is or should be an essential component of any cataract surgery has spread or is spreading beyond subspecialty societies, such as the ASCRS. I do agree that retinal OCT is an additional test that is required prior to multifocal implantation. Some mention was made concerning astigmatism levels in these patients. If possible, it would be helpful to provide more detail on the levels of post- operative astigmatism in these patients (since, as mentioned, MFIOLs perform best with low levels of residual astigmatism/refractive error). Similarly, if available and statistically valid, a more formal comparison of distance-corrected near visual acuity would also be informative. Again, this is a well done study that begins to answer the questions on MFIOL performance relative to monofocal IOLs, although it is very limited by the quality of the available literature. I do believe that a randomized trial in the VA population would be helpful and that the use of these IOLs must be done with a very thorough preoperative work-up, extensive discussion with patients, and an overall conservative philosophy. | Thank you for your comment. Thank you for your comment. We have added this information to the conclusion. We made the change. We made this addition. Thank you for your comment.