# APPENDIX A Search Strategies

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed — 2006/1/1 to 2017/4/30

LANGUAGE:

English

SEARCH STRATEGY:

lenses, intraocular OR lens implantation, intraocular OR accommodation, ocular OR accommodative lens* OR accommodating lens* OR multifocal lens* OR multifocal intraocular lens*

AND

cataract extraction OR cataract*[tiab]

AND

systematic[sb]

Limited to English and 2006-2017