# References

1 Ramchand R, Tanielian T, Fisher MP. Hidden Heroes: America’s Military Caregivers. Santa Monica, CA: Rand Corporation. 2014.
2 Department of Veterans Affairs. What is polytrauma? Available at: https://www.polytrauma.va.gov/understanding-tbi/definition-and-background.asp. Accessed July 20, 2017.
3 Schulz R, Sherwood PR. Physical and mental health effects of family caregiving. Am J Nurs. 2008;108(9 Suppl):23–27; quiz 27.
4 Coe NB, Van Houtven CH. Caring for mom and neglecting yourself? The health effects of caring for an elderly parent. Health Econ. 2009;18(9):991–1010.19582755
5 Wilson MR, Van Houtven, C.H., Stearns, S.C. Depression and missed work among informal caregivers of older individuals with dementia. J Fam Econ. 2007(28):684.
6 Jacobs JC, Van Houtven CH, Laporte A, Coyte PC. Baby Boomer caregivers in the workforce: Do they fare better or worse than their predecessors J Econ Ageing. 2015(6):89–101.
7 Van Houtven CH, Friedemann-Sanchez G, Clothier B, Is policy well-targeted to remedy financial strain among caregivers of severely injured U.S. service members? Inquiry. 2012;49(4):339–351.23469677
8 Van Houtven CH, Coe NB, Skira MM. The effect of informal care on work and wages. J Health Econ. 2013;32(1):240–252.23220459
9 Wolff JL, Spillman BC, Freedman VA, Kasper JD. A national profile of family and unpaid caregivers who assist older adults with health care activities. JAMA Intern Med. 2016;176(3):372–379.26882031
10 Wolff JL, Feder J, Schulz R. Supporting family caregivers of older Americans. N Engl J Med. 2016;375(26):2513–2515.28029922
11 Committee on Family Caregiving for Older Adults. Families Caring for an Aging America. Report from the National Academies of Sciences, Engineering, Medicine. 2016.
12 Dyer EA, Kansagara D, McInnes DK, Freeman M, Woods S. Mobile Applications and Internet-based Approaches for Supporting Non-professional Caregivers: A Systematic Review. VA Evidence-based Synthesis Program Reports. 2012. Available at: https://www.hsrd.research.va.gov/publications/esp/mobile_apps.cfm. Accessed May 10, 2017.
13 Goy E, Kansagara D, Freeman M. A Systematic Evidence Review of Interventions for Non-professional Caregivers of Individuals with Dementia. VA Evidence-based Synthesis Program Reports. 2010. Available at: https://www.hsrd.research.va.gov/publications/esp/dementiacare.cfm. Accessed May 10, 2017.
14 Greenberg G, Hoff R. 2015 Veterans with PTSD Data Sheet: National, VISN, and VAMC Tables. West Haven, CT: Northeast Program Evaluation Center. Annual (2014-Present).
15 Family Caregiver Alliance. National Center on Caregiving. Definitions. Available at: https://www.caregiver.org/definitions-0. Accessed May 15, 2017.
16 Lobban F, Postlethwaite A, Glentworth D, A systematic review of randomised controlled trials of interventions reporting outcomes for relatives of people with psychosis. Clin Psychol Rev. 2013;33(3):372–382.23410719
17 Effective Practice and Organisation of Care (EPOC). EPOC Resources for review authors. Oslo: Norwegian Knowledge Centre for the Health Services; 2015. Available at: http://epoc.cochrane.org/resources/epoc-resources-review-authors. Accessed July 17, 2017.
18 Higgins JPT, Altman DG, Gøtzsche PC, The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343.
19 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–188.3802833
20 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–2710.12939780
21 Agency for Healthcare Research and Quality (AHRQ). Methods Guide for Effectiveness and Comparative Effectiveness Reviews [Internet]. Available at: https://effectivehealthcare.ahrq.gov/topics/cer-methods-guide/overview. Accessed January 16, 2018.
22 Acorn S. Assisting families of head-injured survivors through a family support programme. J Adv Nurs. 1995;21(5):872–877.7601995
23 Bell KR, Temkin NR, Esselman PC, The effect of a scheduled telephone intervention on outcome after moderate to severe traumatic brain injury: a randomized trial. Arch Phys Med Rehabil. 2005;86(5):851–856.15895327
24 Hanks RA, Rapport LJ, Wertheimer J, Koviak C. Randomized controlled trial of peer mentoring for individuals with traumatic brain injury and their significant others. Arch Phys Med Rehabil. 2012;93(8):1297–1304.22840826
25 Powell JM, Fraser R, Brockway JA, Temkin N, Bell KR. A telehealth approach to caregiver self-management following traumatic brain injury: a randomized controlled trial. J Head Trauma Rehabil. 2016;31(3):180–190.26394294
26 Rivera PA, Elliott TR, Berry JW, Grant JS. Problem-solving training for family caregivers of persons with traumatic brain injuries: a randomized controlled trial. Arch Phys Med Rehabil. 2008;89(5):931–941.18452743
27 Sinnakaruppan I, Downey B, Morrison S. Head injury and family carers: a pilot study to investigate an innovative community-based educational programme for family carers and patients. Brain Inj. 2005;19(4):283–308.15832874
28 Winter L, Moriarty HJ, Robinson K, Efficacy and acceptability of a home-based, family-inclusive intervention for veterans with TBI: A randomized controlled trial. Brain Inj. 2016:1–15.
29 Kreutzer JS, Marwitz JH, Sima AP, Godwin EE. Efficacy of the brain injury family intervention: impact on family members. J Head Trauma Rehabil. 2015;30(4):249–260.26147315
30 Togher L, McDonald S, Tate R, Power E, Rietdijk R. Training communication partners of people with severe traumatic brain injury improves everyday conversations: a multicenter single blind clinical trial. J Rehabil Med. 2013;45(7):637–645.23803687
31 Glynn SM, Eth S, Randolph ET, A test of behavioral family therapy to augment exposure for combat-related posttraumatic stress disorder. J Consult Clin Psychol. 1999;67(2):243–251.10224735
32 Weine S, Kulauzovic Y, Klebic A, Evaluating a multiple-family group access intervention for refugees with PTSD. J Marital Fam Ther. 2008;34(2):149–164.18412823
33 Monson CM, Fredman SJ, Macdonald A, Pukay-Martin ND, Resick PA, Schnurr PP. Effect of cognitive-behavioral couple therapy for PTSD: a randomized controlled trial. JAMA. 2012;308(7):700–709.22893167
34 Sautter FJ, Glynn SM, Cretu JB, Senturk D, Vaught AS. Efficacy of structured approach therapy in reducing PTSD in returning veterans: A randomized clinical trial. Psychol Serv. 2015;12(3):199–212.26213789
35 Moriarty H, Winter L, Robinson K, A randomized controlled trial to evaluate the veterans’ in-home program for military veterans with traumatic brain injury and their families: report on impact for family members. PM R. 2016;8(6):495–509.26514790
36 Shnaider P, Pukay-Martin ND, Fredman SJ, Macdonald A, Monson CM. Effects of cognitive-behavioral conjoint therapy for PTSD on partners’ psychological functioning. J Trauma Stress. 2014;27(2):129–136.24706354
37 Shnaider P, Pukay-Martin ND, Sharma S, A preliminary examination of the effects of pretreatment relationship satisfaction on treatment outcomes in cognitive-behavioral conjoint therapy for PTSD. Couple Family Psychol. 2015;4(4):229–238.27840775
38 Martire LM, Schulz R. Caregiving and care-receiving in later life: Recent evidence for health effects and promising intervention approaches. In: Baum A, Revenson T, Singer J, eds. Handbook for Health Psychology. New York: Taylor and Francis. 2012.
39 Glynn SM, Cohen AN, Dixon LB, Niv N. The potential impact of the recovery movement on family interventions for schizophrenia: opportunities and obstacles. Schizophr Bull. 2006;32(3):451–463.16525087
40 Griffin JM, Meis L, Greer N, Effectiveness of Family and Caregiver Interventions on Patient Outcomes Among Adults with Cancer or Memory-Related Disorders: A Systematic Review. VA Evidence-based Synthesis Program Reports. 2013. Available at: https://www.hsrd.research.va.gov/publications/esp/caregiver-interventions.cfm. Accessed May 10, 2017.
41 Meis L, Griffin J, Greer N, Family Involved Psychosocial Treatments for Adult Mental Health Conditions: A Review of the Evidence. VA Evidence-based Synthesis Program Reports. 2012. Available at: http://www.hsrd.research.va.gov/publications/esp/family-interventions-EXEC.pdf. Accessed March 29, 2017.
42 Yesufu-Udechuku A, Harrison B, Mayo-Wilson E, Interventions to improve the experience of caring for people with severe mental illness: systematic review and meta-analysis. Br J Psychiatry. 2015;206(4):268–274.25833867
43 American Psychiatric Association. American Psychiatric Association Practice Guidelines. Acute Stress Disorder and Posttraumatic Stress Disorder (Legacy Collection, 2004). Available at: http://psychiatryonline.org/guidelines. Accessed May 10, 2017.
44 National Institute for Health and Care Excellence (NICE). Post-traumatic stress disorder: management. Clinical guideline [CG26]. March 2005. Available at: https://www.nice.org.uk/guidance/cg26. Accessed May 10, 2017.
45 Department of Veterans Affairs. VA/DoD Clinical Practice Guidelines. Management of Post-Traumatic Stress Disorder and Acute Stress Reaction (2010). Available at: https://www.healthquality.va.gov/guidelines/mh/ptsd/index.asp. Accessed May 10, 2017.
46 Glynn SM. Family-centered care to promote successful community reintegration after war: it takes a nation. Clin Child Fam Psychol Rev. 2013;16(4):410–414.24052145
47 Makin-Byrd K, Gifford E, McCutcheon S, Glynn S. Family and couples treatment for newly returning veterans. Prof Psychol Res Pr. 2011;42(1):47–55.
48 Dixon LB, Glynn SM, Cohen AN, Outcomes of a brief program, REORDER, to promote consumer recovery and family involvement in care. Psychiatr Serv. 2014;65(1):116–120.24177229
49 Sherman MD, Fischer E, Bowling UB, Dixon L, Ridener L, Harrison D. A new engagement strategy in a VA-based family psychoeducation program. Psychiatr Serv. 2009;60(2):254–257.19176422
50 Sherman MD, Fischer EP, Owen RR, Jr., Lu L, Han X. Multi-family Group Treatment for Veterans with Mood Disorders: A Pilot Study. Couple Family Psychol. 2015;4(3):136–149.26336613
51 Sayers SL, Whitted P, Straits-Troster K, Hess T, Fairbank JA. Families at Ease: A national Veteran Health Administration service for family members of veterans to increase veteran engagement in care. Annual Meeting of the Association for Behavioral and Cognitive Therapies. Toronto, Canada 2011. 2011.
52 Breitborde NJ, Moreno FA, Mai-Dixon N, Multifamily group psychoeducation and cognitive remediation for first-episode psychosis: a randomized controlled trial. BMC Psychiatry. 2011;11:9.21226941
53 Van Houtven CH, Smith VA, Stechuchak KM, Comprehensive support for family caregivers. Med Care Res Rev. 2017.
54 Van Houtven CH, Oddone EZ, Hastings SN, Helping Invested Families Improve Veterans’ Experiences Study (HI-FIVES): study design and methodology. Contemp Clin Trials. 2014;38(2):260–269.24837544
55 Department of Veterans Affairs. Caregiver Support (VA-CARES) Evaluation Initiative. Available at: https://www.queri.research.va.gov/partnered_evaluation/caregiver_support.cfm. Accessed May 10, 2017.
56 Martire LM, Lustig AP, Schulz R, Miller GE, Helgeson VS. Is it beneficial to involve a family member? A meta-analysis of psychosocial interventions for chronic illness. Health Psychol. 2004;23(6):599–611.15546228
57 Martire LM, Schulz R, Helgeson VS, Small BJ, Saghafi EM. Review and meta-analysis of couple-oriented interventions for chronic illness. Ann Behav Med. 2010;40(3):325–342.20697859
58 Zubin J, Spring B. Vulnerability--a new view of schizophrenia. J Abnorm Psychol. 1977;86(2):103–126.858828
59 Berliner E, Springs S, Adam G. Augmenting Systematic Reviews with Information from clinicaltrials.gov. Accepted for presentation Eighth International Congress on Peer Review and Scientific Publication September 10-12, 2017, in Chicago, Illinois.
60 Togher L, Power E, Rietdijk R, McDonald S, Tate R. An exploration of participant experience of a communication training program for people with traumatic brain injury and their communication partners. Disabil Rehabil. 2012;34(18):1562–1574.22360709
61 Togher L, McDonald S, Tate R, Rietdijk R, Power E. The effectiveness of social communication partner training for adults with severe chronic TBI and their families using a measure of perceived communication ability. NeuroRehabilitation. 2016;38(3):243–255.27030901
62 Sim P, Power E, Togher L. Describing conversations between individuals with traumatic brain injury (TBI) and communication partners following communication partner training: Using exchange structure analysis. Brain Inj. 2013;27(6):717–742.23672447
63 Weine S, Knafl K, Feetham S, A Mixed Methods Study of Refugee Families Engaging in Multiple-Family Groups. Family Relations. 2005;54(4):558–568.