# Corrigendum

In this updated report (February 13, 2018), we made the following changes:

1. Correctly attributed the findings on caregiver burden to Moriarty et al 2016 instead of Winter et al 2016. These publications reported results from the same study, but the findings about caregiver burden were published by Moriarty and colleagues.
2. As a result of study details published in Moriarty et al 2016, we updated the risk of bias of the overall study from unclear to low. This contributed to a change in the strength of evidence from low to moderate for the meta-analyses that included results published by Winter et al 2016: overall patient function, physical function, and caregiver psychological symptoms. These strength of evidence ratings have been updated.
3. We added Hanks et al 2012 to the meta-analysis for patient physical function after realizing that it had been erroneously omitted; we have updated the results from that meta-analysis throughout the report.