# Stakeholders and Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The list of stakeholders and members of the Technical Expert Panel (TEP) who provided input to this report follows.

## Stakeholders

- Margaret Kabat, LCSW-C
  National Director
  VA Caregiver Support Program
- Shirley Glynn, PhD
  Program Manager
  VA National Family Services Evidence-Based Clinical Training Program

## Technical Expert Panel

- Josephine (Jo) Jacobs, PhD
  Health Economist
  Health Economics Resource Center
- Joel Scholten, MD
  Associate Chief of Staff for Rehabilitation Services
- Ranak Trivedi, PhD
  Research Health Science Specialist
  Center for Innovation to Implementation