# Summary and Discussion

Family caregiver support has been recognized as an important care component for individuals with cognitive impairments, terminal illness, chronic illness, and serious mental illness (SMI).^10,38,39^ Due to recent improvements in battlefield medicine, thousands of US service members return home after combat-related trauma; however, a large proportion must live with substantial physical, social, and emotional functional impairments. Traumatic brain injury (TBI), posttraumatic stress disorder (PTSD), and polytrauma are 3 major issues facing the Veterans Health Administration (VHA) and VA users returning from the conflicts in Iraq and Afghanistan. Due to the rapid increase in the prevalence of these conditions, research about how to implement interventions to support family caregivers has lagged behind the need for such services. Interventions that do exist have adapted the approaches of family caregiver interventions for patients with other conditions, such as aging patients with dementia. In this systematic review, we extend the literature about interventions for family caregivers of patients with cognitive impairments or SMI to understand whether these interventions have beneficial effects for caregivers and patients with TBI, PTSD, and polytrauma.

Our review differs from prior reviews in several ways. This is the first systematic review to examine family caregiver interventions for patients with TBI, PTSD, or polytrauma. Other systematic reviews have examined the effectiveness of family caregiver interventions for elderly patients with cognitive and functional impairments,^13,40^ patients with cancer,^40^ patients with SMI,^16,41,42^ and patients with mental illness more broadly.^41^ The patient population included in the studies we identified had cognitive and functional impairments but were not elderly. We also found no prior reviews that examined interventions for family caregivers of patients assessed to have TBI or polytrauma. For PTSD, the review by Meis and colleagues^41^ captured one of the same PTSD studies we did.^31^ However, our review differed from this prior review in that we included caregiver interventions for patients with TBI and our review of PTSD studies included more recent studies and expanded the scope of the prior review that only considered studies with an RCT design.^41^ Hence, our review fills an important gap in the literature. Specifically, owing to the complex physical, emotional, and social impairments that are common among patients with TBI, PTSD, and polytrauma, caregivers of these patients may have different needs than caregivers of elderly patients or patients with SMI and other mental health conditions. Given the prevalence of TBI, PTSD, and polytrauma among recently returned Veterans and the increasing impetus in VA for programs to support the role of family caregivers, our review has special implications for the VHA and VA users.

## Summary of Evidence by Key Question

### KQ 1 Assessment of the Impact on Care Recipient Outcomes

As expected, the existing literature is small; 13 studies meeting the prespecified review criteria were identified. Strength of evidence was low, heterogeneity across studies was high, and trials included in the meta-analyses contained few patients. Across studies, there was substantial variation in study design, intervention intensity, frequency of contacts, and how or whether disease conditions were defined. The majority of studies enrolled patients with TBI (n=9); no studies enrolled patients with polytrauma. The majority of studies applied an illness education component. Other commonly used components included skills training, social support, and therapy. We found no interventions that provided financial assistance. While individual interventions varied in delivery type, delivery mode, and intensity, most interventions aimed to address similar problems, including reducing caregiver burden, enhancing family function, improving clinical care and the home environment, improving condition-specific symptoms, and increasing family knowledge about health care resources.

### KQ 2 Effects on Care Recipient and Caregiver Outcomes

The studies we examined did not show a consistent intervention effect on caregiver or care recipient outcomes. Of the 4 studies that examined family caregiver interventions for patients with PTSD, 2 evaluated couples-based therapies,^33,34^ 1 evaluated the effect of augmenting prolonged exposure therapy with a family skills-building training intervention,^31^ and 1 evaluated the effect of a multiple-family group education intervention on increased access to mental health care for Bosnian refugees. Couples-based therapies consistently improved PTSD symptoms.^32^ From the TBI literature, quantitative meta-analyses demonstrated no effect of the interventions on overall patient function, physical function, social/emotional function, or psychological symptoms. A meta-analysis restricted to higher-quality trials^25,26,28^ suggested that interventions that include family caregivers may have positive effects on caregiver psychological symptoms. Nevertheless, our findings do not preclude a moderate intervention effect for nonsignificant meta-analyses. Across meta-analyses, confidence intervals were broad, and the mean treatment effect among all studies that examined patient psychological symptoms favored the intervention. Also, qualitative findings suggest that some interventions had statistically significant effects on patient quality of life,^23^ TBI symptoms (eg, communication, memory, and patient-identified symptoms),^27,28,30^ and caregiver burden.^35^ However, the results for quality of life were inconsistent, as 1 study^25^ found no effect for patient or caregiver quality of life and another^26^ found no effect for caregiver quality of life. While 2 of the 3 studies that examined caregiver burden did not find a statistically significant intervention effect on caregiver burden,^26,29^ the effects all favored the intervention, and effect sizes were consistent across studies. Adverse effects and household economic status outcomes were not reported. Only 3 studies examined family function^31,33,34^ and 1 examined mental health service use.^32^

## Strength of Evidence

Strength of evidence (SOE) was rated on the basis of study design, risk of bias, inconsistency, indirectness, and imprecision. (For criteria definitions, refer to the Methods section.) For TBI, the SOE was rated moderate to low for care recipient overall function, physical function, psychological symptoms, and caregiver psychological symptoms and burden. SOE was very low for care recipient mental function. SOE was not rated for adverse effects because no studies reported adverse effects, nor was SOE rated for disease-specific symptoms because the evidence was insufficient. Concerns that contributed to the low SOE were moderate to high risk of bias and imprecision that was attributed to the 95% CI not excluding a moderate effect. There were additional concerns about imprecision that may have been due to poor congruence between outcomes measures.

In Table 6 we summarize the SOE for effects of family caregiver interventions for patients with TBI. Few studies evaluated caregiver interventions for patients with PTSD and these interventions varied substantially. Because of the sparseness of evidence for these comparisons, we only rated the SOE for couples-based therapies for PTSD (Table 7).

Table 6 Strength of Evidence for Effects of Family Caregiving Interventions in TBI

Outcome | Number of RCTs (Patients) | Findings | Strength of Evidence (Rationale by Domain)
Care recipient outcomes
Overall functional status | 3 (238) | SMD 0.29 higher (0.51 lower to 1.08 higher) | Moderate Moderate ROB, consistent, direct, imprecise
Physical functional status | 4 (334) | SMD 0.22 higher (0.11 lower to 0.55 higher) | Moderate Moderate ROB, consistent, direct, imprecise
Mental functional status | 3 (238) | SMD 0.42 higher (0.68 lower to 1.51 higher) | Very Low Moderate ROB, inconsistent, indirect, very imprecise
Psychological symptoms | 3 (293) | SMD 0.25 lower (0.62 lower to 0.12 higher) | Low Moderate ROB, consistent, direct, imprecise
Caregiver outcomes
Psychological symptoms | 3 (296) | SMD 0.32 lower^a^ (0.59 lower to 0.05 lower) | Moderate Moderate ROB, consistent, direct, imprecise
Caregiver burden | 3 (252) | Median effect size 0.31 (range 0.30 to 0.35) p=NS for 2 of 3 studies | Low Moderate ROB, consistent, direct, imprecise

a SMD and SOE rating reported are from the sensitivity analyses excluding the single high risk of bias study.

Abbreviations: RCT=randomized controlled trial; ROB=risk of bias; SMD=standardized mean difference; TBI=traumatic brain injury

Table 7 Strength of Evidence for Effects of Family Caregiving Interventions in PTSD

Outcome | Number of RCTs (Couples) | Findings | Strength of Evidence (Rationale by Domain)
Care recipient outcomes
PTSD symptoms | 2 (97) | Clinically improved symptoms by clinician interview (range 23.2 to 27.6)^a^ and patient report | Moderate Unclear ROB, consistent, direct, precise
Interpersonal relationships | 2 (97) | Improved as reported by the patient but not the caregiver | Low Unclear ROB, inconsistent, direct, precise

a Clinician-administered PTSD scale.

Abbreviations: PTSD=posttraumatic stress disorder; ROB=risk of bias

## Clinical and Policy Implications

Clinical practice guidelines for patients with TBI, PTSD, or polytrauma offer only general recommendations regarding the role of families and caregivers.^43–45^ For example, the VA/DoD clinical practice guidelines for the Management of Posttraumatic Stress Disorder and Acute Stress Reaction^45^ recommends educating trauma survivors and their families about PTSD, including practical ways of coping with traumatic stress symptoms, the process of recovering, and treatment options. However, these guidelines do not make recommendations beyond education or nonspecific suggestions for family interventions. Our update of interventions to support family caregivers and patients with PTSD, TBI, or polytrauma, along with other relevant VA ESP systematic reviews,^12,40,41^ should be considered by guideline panels. Given the large investment the VHA has made in caregiver support programs, it would be helpful to clinicians if guidelines addressed available programs more specifically.

Our findings are similar to those of prior high-quality systematic reviews that examined the impact of interventions for caregivers of patients with mental illness, cognitive impairment, and cancer on both caregiver outcomes^13,16,42^ and patient outcomes.^40,41^ These prior reviews found few high-quality studies, and there was high heterogeneity across studies. These reviews found qualitative positive effects for some interventions on outcomes.^16,41^ Only 1 review^42^ found quantitatively positive effects of illness education and support interventions on caregiver psychological distress. Evidence from the VA ESP systematic review that examined caregiver interventions for patients with either cancer or memory disorders did not favor family-involved interventions over usual care on functional, psychological, quality of life, symptoms control or health service use,^40^ but another VA ESP systematic review that examined caregiver interventions for caregivers of elderly patients with dementia found some promise for multicomponent interventions on caregiver psychological, burden, and quality of life outcomes.^13^ The findings from that review suggest that more intensive and tailored interventions occurring after a home visit are more effective. Finally, another high-quality VA ESP systematic review examined the effect of technology in supporting caregivers.^12^ However, the interventions examined in that review, including handheld/tablet computers, wireless/mobile technology, iPad, m-Health, internet-based interventions, text messaging, and other informatics applications, were not similar to interventions examined in other studies, which generally involved an interventionist or peer coach/mentor. In sum, across disease conditions and types of interventions, there is no clear message about the beneficial effects of family caregiver interventions on outcomes, and in general the quality of the evidence is low. However, there is some suggestion from our review and 2 prior reviews that these interventions might have some benefit for caregiver psychological outcomes, including psychological symptoms and caregiver burden.^13,42^

The implications of our review for VA are unclear. Only 4 identified studies recruited a sample of VA users,^28,31,33,34^ and it is likely that the sequela of combat-related trauma versus trauma experienced by the mostly civilian patient samples identified in this review differ. However, within VA, interest in interventions to support family caregivers as part of a wider movement to promote Veteran health is growing,^46,47^ and there are likely some lessons learned about intervention delivery and outcome measurement that could inform research and implementation efforts in VA.

VA offers robust programs to support Veterans and their family caregivers through evidence-based therapies for family members of Veterans with mental illness,^46,47^ family engagement interventions,^48–51^ and family support interventions.^52^ In addition, the VA PCAFC is a national program that supports caregivers of Veterans through the provision of a mandatory skills training, stipend, health insurance, respite care, travel support, and contact with specialized VA staff to facilitate referrals and connections. Among Veterans in PCAFC, 70% have a PTSD diagnosis and 30% have a TBI diagnosis.^53^ Within PCAFC, family caregivers can choose from multiple services (except skills training and stipend, which are mandatory) and therefore it is difficult to apply the findings from this review of specific interventions to broad policy implications for PCAFC. However, specific PCAFC services (eg, skills training, support groups) and other family service interventions in VA, such as Homefront, a group family education program for family members of Veterans with mental illness, use similar strategies as the interventions we examined in this review, including psychosocial education, social support, and therapy. Therefore, this review has the potential to inform the content and delivery of these specific components. Unfortunately, the dearth and low quality of existing literature makes it challenging to compare and contrast optimal delivery strategies and content and their effect on outcomes. Despite this we offer some thoughts:

- While family caregiver interventions for patients with TBI, PTSD, and polytrauma may be useful, the existing interventions attempt to accomplish many goals. In fact, the goals of each study examined in this review were fairly diffuse, the intensity of the interventions substantially different, and in some cases it was unclear the degree to which family members were involved. Instead, it may be more effective to focus on 1 or 2 outcome goals and then refine content, delivery strategy, target participant (ie, care recipient vs caregiver), and intervention intensity to specifically address those outcomes. For example, one study focused primarily on addressing current problems with patients with TBI and involved caregivers when possible.^23^ Relative to all other studies identified in this review, this phone-based intervention had the strongest effect on patient psychological and functional outcomes. Perhaps this intervention was effective because the study had a clear target: the care recipient.
- Important patient- and caregiver-centered outcomes may be difficult to quantify. Several studies have found high levels of satisfaction with the intervention, but no change in caregiver burden or psychological distress scores.^22,54,55^ Relatedly, it may be necessary to rethink what constructs caregiver interventions actually impact (eg, success gaining information from a provider^25^ or high satisfaction^22^) and identify validated measures for these outcomes that are used consistently across studies.^16^ Some of the constructs being measured (eg, depressive symptoms) were designed for clinical populations and may not reflect the distress experienced by caregivers. Problems related to trauma are complex and multidimensional.^28^ As such, intervention outcomes may not map directly onto domains of existing instruments.
- Several studies questioned whether short-term follow-up periods, such as a year or less, are sufficient to identify changes in psychological symptoms and other outcomes.^22,25^ Yet, it is also possible that the interventions may have lacked the intensity and targeting needed to observe positive intervention effects no matter the length of the follow-up period.^13^ For the meta-analyses presented in this review, length of time of the intervention or follow up period did not appear to be related to whether outcomes were positive or negative.

Some established literature about the impact of family members on outcomes of patients with chronic disease has identified potential behavioral mechanisms that explain these effects.^38,56,57^ While the stress-vulnerability theory^58^ demonstrates how and why a family caregiver would provide benefit for patients, many of the studies did not identify specific theoretical underpinnings for the intervention design. Therefore, future research should identify and apply theoretical models are needed to inform discrete study goals, intervention designs, testable hypotheses, and explanations for the observed findings. Such theoretical models would provide a benchmark for more in-depth analysis about what did and did not work and would thus move the field forward.

## Limitations

This review has several limitations. Studies were limited to those from OECD countries in the Western hemisphere and articles published in English. Identifying eligible studies was difficult because structured search terms do not fully capture the broad range of eligible interventions we considered in the review. Further, the role of the caregiver depends on the condition; for example, for patients with TBI, family members are often referred to as a family caregiver because needed care may have a more clinical focus, such as help with activities of daily living. In contrast, “caregivers” of patients with PTSD are rarely conceptualized as being labeled a caregiver, but rather a supportive family member or friend. In addition, the studies typically did not give detailed eligibility criteria for the caregivers. Therefore, from these studies, it is difficult to glean much about how to target caregivers who are likely to help the Veteran. Studies for which family involvement was either causal or unplanned were not included in this review. Most studies evaluated illness education, skills-based, or therapy-based interventions. We found no studies that examined interventions to improve household economic status. There were also no policy evaluations that met our criteria for inclusion. One study that showed positive effects of the PCAFC on increased mental health, primary care, and specialty care for Veterans with PTSD did not meet EPOC study design criteria.^53^ Other limitations are described below.

### Publication Bias

Given the small number of studies, statistical methods to detect publication bias are not useful. Other strategies, such as searching ClinicalTrials.gov for completed but unpublished studies is theoretically appealing but in practice has not been found useful.^59^

### Study Quality

We were also limited by the existing literature. We identified few studies, and most were assessed as moderate to high ROB. Study samples were small and the measures used may not have accurately captured the phenomena of interest. Use of patient- and caregiver-reported outcomes, which may be better measures of intervention effectiveness,^22,25^ was rare. No studies reported adverse effects. Several studies did not clearly describe the study design, control group, and intervention procedure in order for the team to assess ROB; for example, for one study it was unclear whether the patients had been randomized or not.^24^ While most control groups were “treatment as usual,” how this was defined and what type of care it included was rarely defined.

### Heterogeneity

Unexplained heterogeneity evident in some of our meta-analyses represents another limitation of the existing evidence. We compared interventions that varied substantially in goals, delivery, intensity, and target recipient. We found that interventions varied in intensity, frequency of contact, duration, delivery strategies, goals, and outcome measures used. Usual care comparators were not well described. In some cases, poor descriptions of the study sample and baseline severity also made it difficult to compare how sample differences contributed to the observed heterogeneity. Finally, it was difficult to determine whether the care recipient or the caregiver was the target of the intervention and how involved the family member was when the intervention focused on the patient. Studies often did not describe the planned versus the actual role of the family member in the intervention, which added a layer of complexity when trying to conduct cross-study comparisons. We also compared outcome measures that may not have measured precisely the same constructs though we attempted to pool only measures that were conceptually similar. For example, the meta-analysis of social/emotional function used measures that compared cognitive function with mental and social function. However, we carefully considered which outcome measures could be reasonably pooled and we presented standardized mean differences to show effect sizes. We also only combined studies with an RCT design and we considered qualitatively whether meta-analysis findings differed by intervention format and delivery strategy and found little evidence to suggest that variations in study format impacted observed effects across studies.

### Applicability of Findings to the VA Population

Of the 13 studies, 4 (31%) were conducted specifically in Veterans, and thus are highly applicable to the Veteran population. These studies did not differ qualitatively in important ways from studies containing non-Veteran samples. All but 2 studies were conducted in North America, and the rest were conducted in other economically developed countries. Most studies were conducted after 2005. However, many of the studies enrolled patients with TBI sustained in noncombat situations. Veterans with TBI often have coexisting PTSD, and thus findings in civilian patients may not generalize well to Veterans. A caution that is applicable to trials in general is that trials tend to enroll patients who are not representative of the underlying target population, and thus interventions are often less effective when implemented in routine clinical practice.

## Research Gaps/Future Research

We structure our reflection of gaps in evidence by considering each element of the PICOT framework (Table 8). Although it would be possible to generate an extensive list of gaps in evidence, we restricted this list to the areas judged to be highest priority, given the current state of evidence. To facilitate future literature syntheses, we encourage investigators conducting clinical trials to include these studies in trial registries.

Table 8 Highest-priority Evidence Gaps

PICOT Domain | Evidence Gap
Population | No evidence in patients with polytrauma; sparse evidence in those with PTSD. No evidence on caregivers and patients most likely to benefit.
Interventions | Uncertainty about the relationship between outcomes and intervention dose, mode of delivery, and components. Effects of financial support have not been studied in an eligible design. Study designs are needed to incorporate patient and caregiver/stakeholder input. Need to better quantify the role of the family member, and using a dichotomy to describe the role, such as “family assisted” versus “family oriented,” would be helpful compare interventions across studies. Intervention development should be informed by conceptual models.
Comparators | Caregiver versus dyadic interventions; better descriptions of usual care are needed.
Outcomes | Few studies report care recipient outcomes. Outcome measures vary greatly across studies making synthesis difficult. Measures are needed that capture patient/caregiver reported outcomes, including intervention satisfaction and acceptability, quality of life, and changes in employment/household income.
Timing | Need randomized controlled trials of combined treatments that include economic outcomes, especially over time.

The VHA may be uniquely well-suited to addressing these gaps in evidence. Further, the population served and the resources committed give the VA the needed platform to address these gaps. The prevalence of TBI, PTSD, and polytrauma is enriched in the enrolled VA population compared with other US health care systems. Given that these interventions often represent changes in the delivery of health services, a variety of study designs, including randomized trials and quasi-experimental designs will be appropriate. In addition, the VA invested in a large caregiver support program for OEF/OIF Veterans and a partnered evaluation unit to assess the program. Findings from an evaluation of PCAFC show that participation in the program was associated with increases in mental health care, primary care, and specialty care services for all enrollees and enrollees with a PTSD diagnosis^53^; however, future research related to PCAFC evaluation should focus on specific programmatic elements and their effects on health and health service use outcomes. More broadly, identifying caregiving as a funding priority connected to specific RFAs within VA ORD would help to support investigators to conduct research that can fill the identified gaps. Specifically, RFAs that focus on caregivers or partners alone are critical to promote family resilience and unity and would provide key benefits to Veterans even if the studies do not directly address Veteran functioning.

## Conclusion

There is a small but growing literature about family caregiver interventions for patients with trauma-based conditions, including TBI and PTSD. Overall, we identified a diverse set of interventions; the majority included a family illness education component, and many utilized skills-based curricula to promote environment modifications, improvements in condition-specific skills, caregiver self-care, and coping skills. Evidence about the impact of these interventions on patient and caregiver outcomes is inconclusive given the small literature, few patients, and the heterogeneity of intervention format, delivery, intensity, family involvement, and outcomes. Yet for several outcomes, such as caregiver burden and psychological symptoms, caregiver interventions may be a promising approach. The positive impact of caregiver interventions on caregiver distress aligns with some prior reviews across a variety of patient conditions^13,42,56^; however, there remain considerable gaps. No studies have been published that examine caregiver interventions for individuals with polytrauma; none that were eligible examined financial assistance interventions; few examined patient/caregiver reported outcomes; and study quality was low.