# Results

## Report Organization

The results are organized into 3 sections: literature flow, KQ 1 results, and KQ 2 results. In the results sections for key questions, we describe the key findings, followed by detailed descriptions of the included studies. For KQ 2, which describes the effects of the interventions, we organize the outcomes by condition and within condition, by care recipient, caregiver, and household outcomes.

## Literature Flow

Figure 1 shows the flow of articles through the literature search and screening process. The literature search identified 2837 unique citations from a combined search of MEDLINE (via PubMed (n=1319)), PsycINFO (n=149), and CINAHL (n=1369). An additional 73 articles were identified from manual searches of bibliographies and current literature published after the search date, for a total of 2912 unique citations. After applying inclusion and exclusion criteria at the title-only screening level, 526 were promoted to full-abstract screening. After applying criteria at the full-abstract level and removal of 23 systematic reviews, the citations were culled down to 126 articles for full-text review. Of these, 19 were retained for data abstraction (13 primary papers and 6 companion papers).

Figure 1 Literature Flow Diagram

* Search results from CINAHL (1369), PubMed (1319), PsycINFO (149), and manual (75).

Among the 13 included primary studies, 10 were randomized controlled trials (RCTs), 2 were nonrandomized trials, and 1 was an interrupted time series design. All 13 primary studies were applicable to both KQs and most were conducted in the United States (n=10).

A search of clinicaltrials.gov for caregiving and our 3 conditions of interest produced 72 entries, 58 of which were not applicable; 14 entries may produce applicable results in the future, but all interventions are along the same lines as studies included in our report. Only 1 entry addressed polytrauma, but it was an observational study that would not meet our criteria. There was no evidence of publication bias.

## Key Question 1 For which patient groups (ie, patients with posttraumatic stress disorder, traumatic brain injury, or polytrauma) that receive interventions that involve family members has the impact on care recipient outcomes been assessed?

### Key Points

- We identified 13 studies evaluating caregiving interventions for family caregivers of patients with PTSD or TBI, 10 of which assessed the impact on care recipient outcomes.
- Most studies enrolled caregivers of patients with TBI (n=9).
- No studies enrolled patients assessed to have polytrauma.
- The most commonly reported care recipient outcomes were physical or mental functional status and psychological status (eg, depression severity).^22–28^

### Detailed Findings for KQ 1

We identified 13 studies that assessed patient-focused psychological or rehabilitation treatments with family member involvement for patients with PTSD or TBI (Table 3). Nine studies evaluated interventions for caregivers of patients with TBI.^22–30^ Four studies evaluated interventions for caregivers of patients with PTSD.^31–34^ One TBI study also examined PTSD diagnoses and found frequent comorbidity (67%).^28^ We did not identify any intervention studies for caregivers of patients with polytrauma.

Table 3 Evidence Profile for Family Caregiving Studies (n=13)

| TBI Studies (n=9) | PTSD Studies (n=4)
Study designs | 6 RCTs 2 nonrandomized trials 1 interrupted time series | 3 RCTs 1 cluster RCT
Study years | 1995, 2005 (2 studies), 2008, 2012, 2013, 2015, 2016 (2 studies) | 1999, 2008, 2012, 2015
Number of patients | 1,148 | 324
Number of caregivers (studies NR) | 673 (2 studies NR) | 97 (2 studies NR)
Mean patient age (range) reported in # of study arms (studies NR) | 38.7 (30.3-44.6) reported in 18 study arms (2 studies NR) | 38.0 (32.6-46.7) reported in 9 study arms
Mean caregiver age (range) reported in # studies | 48.6 (41.2-51.8) reported in 6 studies | 34.5 (32.2-40.7) reported in 2 studies
Intervention Setting | Care recipients living in the community | Care recipients living in the community
Patients are Veterans | 1 study | 3 studies
Countries | USA (6), Canada (1), United Kingdom (1), Australia (1) | USA (4), Canada (1)^a^

a One study was conducted in both the United States and Canada.

Studies were conducted between 1995 and 2016, with the majority (77%) since 2005. Among the 12 multiarm studies (1 study was a single-arm interrupted time series design^22^), 10 studies had 2 arms, and 2 studies had 3 arms, for a total of 14 comparisons with patient-focused, family-involved interventions. Interventions were compared with waitlist or inactive comparators in 5 studies, usual care in 4, and active comparators in 4 studies. One study was an interrupted time series design and the 1 arm was its own comparator. The intervention target was both caregiver and care recipient in 6 studies, only the care recipient in 3 studies, and only the caregiver in 4 studies. Delivery type was one-on-one in 9 studies, group in 3 studies, and both in 1 study.^30^ In-person was used as the mode of delivery in 10 studies, and in 7 of those it was the only mode used. Phone was used in 5 interventions, usually in combination with in-person or written communication. Eight different disciplines were used for the interventionist. The only disciplines occurring more than once were psychologist (n=4) and social worker (n=2). Frequency and duration varied greatly. Frequency of sessions ranged from 3 to 16, but in the 3-session intervention study, the intervention was 10 hours in duration. The duration of other sessions ranged from 30 minutes to 2.5 hours. The duration of entire interventions ranged from 10 weeks to 2 years, with a median of 14 weeks; 2 studies did not report the intervention duration.^26,27^

Studies included 2 of the prespecified intervention components on average (range 1-4). The majority of interventions included illness education (n=12, 92%) and skills training (n=9, 69%). Seven studies included another type of component, usually help with resource navigation (n=3) or written materials such as homework or handouts (n=3) to complement illness education. Five studies (38%) included a therapy aspect: behavioral family therapy, couples therapy, problem-solving therapy, or individual therapy sessions,^26,30,33,34^ and another 3 studies included an aspect such as emotional support in caregiver groups.^22,24,32^ There were no studies that offered financial assistance or other practical assistance, such as respite care, as part of the intervention.

The outcomes reported are summarized in Figure 2. Three studies reported outcomes for caregivers only,^22,26,29^ 4 studies reported outcomes for care recipients only,^23,30–32^ and 6 studies reported both caregiver and care recipient outcomes.^24,25,27,28,33,34^ Three studies reported family-level outcomes including family functioning; none reported household economic status.^24,33,34^ The most commonly reported outcomes included psychological status in 9 studies, caregiver burden in 3 studies, quality of life in 3 studies, and family functioning in 3 studies. No studies reported on any type of adverse events or clinical eligibility for specific programs or services. A variety of measurement instruments were utilized for each outcome category. A table of outcome measures abstracted for this review is included in Appendix C. Timing of outcome measurement varied widely across studies, as intervention duration ranged from 2.5 months to 1 year (and up to 2 years in a subset of 1 study).

Figure 2 Frequency of Outcomes Reported in Caregivers and Care Recipients (left) and Care Recipients Only (right)

## Key Question 2 What effects do programs or strategies to support or train family caregivers have on care recipient and caregiver outcomes?

### Key Points

- Interventions that included family caregivers did not improve overall functional status, physical functional status, emotional/social function status, or psychological symptoms for the TBI care recipient. However, these outcomes were reported in only a few studies, and the 95% CI did not exclude a moderate effect (low to very low strength of evidence [SOE]).
- Interventions that included family caregivers showed positive effects for psychological symptoms of the TBI caregiver^25,26,28^ (moderate SOE).
- Qualitative synthesis demonstrated a consistent pattern of small beneficial effects of the interventions on TBI caregiver burden; however, only 1 of the 3 studies found a statistically significant effect of the intervention on caregiver burden.^35^
- Two forms of couples therapy for PTSD showed consistent improvements in PTSD-related symptoms and some other psychological symptoms for PTSD care recipients; patient-reported, but not partner-reported, relationship quality improved (moderate SOE).
- There is preliminary evidence from 1 study that caregiver involvement may improve mental health treatment-seeking and engagement for refugees with PTSD.^32^
- The evidence is insufficient to determine if evidence-based treatment for PTSD, with additional augmentation by family-based skills building intervention, improves PTSD caregiver or care recipient outcomes; however, one evidence-based couples-based treatment for PTSD (cognitive behavioral conjoint therapy [CBCT]) found a significant positive effect of the intervention on psychological symptoms for partners who were in the distressed range at pretreatment.^36^
- Care recipient independence, adverse effects, clinical eligibility for specific programs or services, and household economic status were not examined in any identified study.

Next, we present detailed findings for KQ 2 beginning with TBI studies, followed by PTSD studies, and then quality of evidence for both.

### Detailed Findings for TBI

Nine studies evaluated the effect of patient-focused interventions that included family caregivers on outcomes for patients with TBI and their caregivers.^22–30^ Six studies were RCTs.^23–28^ Except for a single 4-arm trial,^24^ all trials had 2 comparison arms. Of the 3 nonrandomized studies, 2 used a controlled pre-post design,^29,30^ and 1 used an interrupted time series design.^22^ Across the 9 studies, 100% of patients were classified as having TBI. Only 1 study assessed comorbid PTSD.^28^ In total, there were 1,148 care recipients and 673 family caregivers. One study included only Veteran participants.^28^ Mean participant age ranged from 30.3 to 44.6 years. Definitions of TBI varied but included self-report of a head trauma,^22,24,29,30^ the Glasgow Coma Scale,^23,27^ and the VA Criteria for TBI.^28^ Recruitment settings included inpatient,^23,25^ outpatient,^28,30^ rehabilitation units,^24,27^ and community settings.^22,26,29^

Interventions and modalities (Appendix B) varied across studies and ranged from less structured mentored telephone calls^24^ to specific therapeutic interventions.^25,26,28,29^ However, common intervention strategies included family illness education, skills-building for TBI recovery, problem-solving, and psychosocial support. Of the 4 studies evaluating specific therapeutic interventions, 1 RCT used the Veterans’ In-home Programme (VIP) intervention,^28^ which included 6 in-home visits and 2 follow-up telephone contacts with an occupational therapist that focused on patient and family members problem-solving environmental challenges in the home. Two studies used problem-solving therapy.^25,26^ One study with high risk of bias (ROB) used the Brain Injury Family Intervention, a structured family therapy treatment program based on principles of cognitive behavioral therapy to enhance family function.^29^ Another high ROB study paired peer mentors with TBI patients and their family caregiver to discuss topics of relevance for families with a TBI survivor.^24^ Other studies used group illness education approaches for family caregivers and care recipients^22,27,30^; these group sessions covered topics such as managing cognitive and behavioral problems associated with TBI, emotional coping skills, communication, and goal-setting. One low ROB study used motivational interviewing for problem-solving related to patient-identified and family caregiver-identified issues.^23^

Group, individual, and telephone modalities were used across and within studies. Five studies used in-person components,^24,26,28–30^ 5 studies delivered part of the intervention over the telephone,^23–26,28^ and 3 delivered content through group sessions.^22,27,30^ The number of planned sessions ranged from 4^27^ to 17.^24^ Planned session duration varied from 10 hours per weekend^22^ to 30-45 minute phone calls^23,24^; total planned intervention duration across all sessions ranged from fewer than 10 hours to 35 hours.

Comparison interventions included active control (education^26^), inactive control (treatment as usual^23–25,28^) and waitlist controls.^27,29,30^ One study was an interrupted time series and thus individuals served as their own control over time.^22^ One trial^24^ describes 4 arms, but reports outcomes for only 1 comparison: mentored patients and caregivers versus patients and caregivers without mentoring.

Using the Cochrane Risk of Bias Criteria,^18^ ROB was judged low for 3 studies,^23,25,28^ unclear for 2 studies,^22,26^ and high for 4 studies.^24,27,29,30^ Table 4 summarizes findings for TBI studies.

Table 4 Summary of Findings for TBI Studies

Study Target | N Enrolled Veterans? | Study Design Comparison | Mean Age in Years (SD) % Female | Outcomes Reported | Overall Risk of Bias
Acorn, 1995^22^ Caregiver | 33: 19 caregivers 14 care recipients Unclear | Interrupted time series Illness education and social support (before and after) | [underlined: Caregiver] 50 (range 26-69) 74% [underlined: Care recipient] 34 (range 15-60) 29% | [underlined: Caregiver] Quality of life Psychological (well-being) [underlined: Care recipient] NR | Unclear
Bell, 2005^23^ Care recipient | 171 Unclear | RCT Illness education and resource access vs treatment as usual | [underlined: Caregiver] NR [underlined: Care recipient] 35 (15.0) %NR | [underlined: Caregiver] NR [underlined: Care recipient] Quality of life Functional status (physical and mental) Psychological (mood) | Low
Hanks, 2012^24^ Care recipient | 158: 62 caregivers 96 care recipients Yes | RCT Illness education, social support, and resource access vs treatment as usual | [underlined: Caregiver] 51.0 (12.0) 45% [underlined: Care recipient] 39.7 (17.5) 10.5% | [underlined: Caregiver] Family function Psychological (mood) [underlined: Care recipient] Functional status (physical and mental) Psychological (mood) [underlined: Aggregate] Family function | High
Kreutzer, 2015^29^ Caregiver | 154 Unclear | Nonrandomized Illness education, skills training, and homework vs waitlist | [underlined: Caregiver] 51.2 (IQR 40.6-62.1) 72.2% [underlined: Care recipient] 41.5 (IQR 25.6-52.3) %NR | [underlined: Caregiver] Burden [underlined: Care recipient] NR | High
Powell, 2016^25^ Caregiver | 153 Unclear | RCT Illness education and skills training vs treatment as usual | [underlined: Caregiver] 49.6 (13.5) 82.3% [underlined: Care recipient] 42.3 (20.2) 24.8% | [underlined: Caregiver] Quality of life Psychological (mood) [underlined: Care recipient] Quality of life Functional status (mental) | Low
Rivera, 2008^26^ Caregiver | 67 Unclear | RCT Therapeutic aspects and skills training vs education control | [underlined: Caregiver] 51.1 (12.2) 92.5% [underlined: Care recipient] 36.9 (14.5) 25.3% | [underlined: Caregiver] Burden Quality of life (satisfaction) Psychological (mood) [underlined: Care recipient] NR | Unclear
Sinnakaruppan, 2005^27^ Caregiver and care recipient | 99: 50 caregivers 49 care recipients Unclear | RCT Illness education, skills training, and handouts vs waitlist | [underlined: Caregiver] NR 78.6% [underlined: Care recipient] 44.1 (10.3) 21.9% | [underlined: Caregiver] Psychological (mood) [underlined: Care recipient] Functional status (physical and mental) Psychological (mood) | High
Togher, 2013^30^ Caregiver and care recipient | 44 Unclear | Nonrandomized Illness education, therapeutic aspect, and skills training vs waitlist or patientonly treatment | [underlined: Caregiver] 49.7 (13.6) 79.3% Care recipient 35.2 (12.3) 13.8% | [underlined: Caregiver] NR [underlined: Care recipient] Disease-specific (TBI symptoms) | High
Winter, 2016^28^ Moriarty, 2016^35^ Care recipient | 162: 81 caregivers 81 care recipients Yes | RCT Illness education, skills training, and resource access vs enhanced treatment as usual | [underlined: Caregiver] 41.6 (12.6) 93.8% [underlined: Care recipient] 40.1 (13.1) 13.6% | [underlined: Caregiver] Psychological (mood) Burden [underlined: Care recipient] Functional status (physical and mental) Psychological (mood) | Low

Abbreviations: IQR=interquartile range; NR=not reported; RCT=randomized controlled trial; SD=standard deviation; TBI=traumatic brain injury

#### TBI: Care Recipient Outcomes

##### Quantitative Summary

Meta-analyses were conducted for 4 patient-level outcomes. These analyses included 5 RCTs^23–25,27,28^ (455 patients) and were conducted for overall functional status, physical functional status, social/emotional function status, and psychological symptoms. Interventions evaluated across the 5 RCTs included the Veteran’s In-home Program (VIP), consisting of in-home visits and telephone contacts with the family member to implement coping strategies,^28^ group illness education,^27^ telephone counseling using motivational interviewing for problem solving that targeted both family caregivers and care recipients,^23^ problem-solving therapy with TBI family caregivers,^25^ and patient and significant other mentoring on topics such as disease education and relationship skills (ie, building trust, problem-solving, goal-setting).^24^ The number of contacts across interventions was similar. For the meta-analyses, data from the last assessment time point was used, and this time point generally coincided with end of treatment, except for 2 studies for which only data from a 3-month post-intervention follow-up was available,^23,27^ and 1 study for which only data from 1 month after the intervention was reported.^24^ One study did not define the length of the intervention.^27^ Assessment time points ranged from 4 months^28^ to 12 months.^23,26^

[underlined: Overall functional status.] Outcome measures for overall functional status included the Patient Competency Rating Scale (PCRS),^28^ the Functional Independence Measure (FIM),^27^ and the SF-36 Physical and Mental Subscales averaged across patients.^23^ There was no effect of the interventions on overall functional status of patients with TBI (SMD 0.29, 95% CI -0.51 to 1.08, I^2^=43.3%, Q=3.5, p=0.17) (Figure 3). However, confidence intervals were broad and do not exclude a moderate effect of the intervention. Heterogeneity was moderate, but not statistically significant (I^2^=43.3%, Q=3.5, p=0.17); it is possible that the social and emotional functional status subscales in the measures of overall functional status did not represent similar constructs. Also, interventions varied in content, delivery, and format.

Figure 3 Forest Plot of Overall Functional Status for TBI Care Recipients

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

[underlined: Physical functional status.] Outcome measures for physical functional status included the physical function subscale from the PCRS,^28^ the motor subscale from the FIM,^27^ the SF-12,^24^ and the SF-36 physical function subscale.^23^ Results showed no effect of interventions for family caregivers and patients on the overall functional status of patients with TBI (SDM 0.22 95% CI -0.11 to 0.55, I^2^=0%, Q=2.6, p=0.46) (Figure 4). However, confidence intervals were broad and do not exclude a moderate effect of the intervention.

Figure 4 Forest Plot of Physical Functional Status for TBI Care Recipients

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

One study reported 2 measures for patient physical function: the FIM functional independence measure and a functional status composite from the Functional Status Examination (FSE).^23^ Results from the FIM were included in the meta-analysis reported above. The between-group mean difference from the FSE favored the intervention, but similar to the FIM, results were not statistically significant (2.1, 95% CI -0.6 to 4.7).

[underlined: Emotional/social functional status.] Outcome measures for social/emotional functional status included the emotional function subscale from the PCRS,^28^ the cognitive subscale from the FIM,^27^ and the SF-36 mental function subscale.^23^ Results showed high statistical heterogeneity (I^2^=63.3%, Q=5.4, p=0.07), and thus we do not report a summary estimate of effect (Figure 5). The median intervention effect was 0.43 (SDM range 0.95 to 0.01). We examined the studies qualitatively to identify potential sources for the observed heterogeneity and believe that the measures of social and emotional functional status measured dissimilar constructs. For example, the FIM measured cognitive functional status while the SF-36 measured psychological symptoms and social participation. Refer to the “Overall functional status” paragraph above for more discussion.

Figure 5 Forest Plot of Emotional/Social Functional Status for TBI Care Recipients

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

[underlined: Psychological symptoms.] Outcome measures for psychological symptoms included the Brief Symptom Inventory (BSI) total score^23,25^ and the average of the anxiety and depression subscales of the Hospital Anxiety and Depression Scale (HADS).^27^ Results demonstrated no effect of interventions for family caregivers on TBI care recipient psychological symptoms (SDM -0.25, 95% CI -0.62 to 0.12, I^2^=0.00; Q=1.1, p=0.58) (Figure 6). While not significant, the direction of the results favors the intervention.

Figure 6 Forest Plot of Psychological Symptoms for TBI Care Recipients

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

Two studies not included in a meta-analysis because of differences in study design or outcome measure examined the association between a family intervention and family caregiver psychological symptoms post-intervention using the General Well Being Scale^22^ and the BSI.^24^ The study that used an interrupted time series design found no significant pre-post change in the score (scores from the 3 post-intervention time points were averaged together).^22^ The other study also found no effect of the intervention on care recipient psychological symptoms (Cohen’s d=0.31, p=0.21, n=62) at end of treatment (12 months).^24^

One study had consistently strong intervention effects on the patient outcomes of interest.^23^ We examined this study qualitatively to understand whether components of the intervention or the study sample drove these effects. We were unable to identify a definitive reason for these differences. The intervention reported was the least intensive, both in regard to delivery format and number/frequency of contacts, and the patient was the primary target of the intervention. In addition, the intervention addressed immediate concerns using motivational interviewing and problem-solving techniques. Therefore, it is possible that the heightened emphasis on the patient, as opposed to the family caregiver, and the focus on addressing current problems drove the observed effects.

##### Qualitative Summary

Outcomes from studies without an RCT design or without a sufficient number of studies to do a meta-analysis are described qualitatively below. These studies reported changes in functional status, quality of life, and TBI symptoms. Care recipient outcomes related to independence, health service use, and adverse effects were not reported.

[underlined: Quality of life.] Two studies evaluated the effect of interventions involving family caregivers on care recipient quality of life.^23,25^ One study used the Life Satisfaction Scale and found no intervention effect at end of treatment (6 months).^25^ The other study found significant between-group mean differences from the EuroQoL and the Perceived Quality of Life (PQOL) scale favoring the intervention (mean difference from EuroQOL=0.10, 95% CI 0.02 to 0.19; mean difference from PQOL=8.8, 95% CI 1.7 to 15.9).^23^

[underlined: TBI symptoms.] Several studies evaluated improvements in TBI symptoms as a result of the interventions. One study found that participation in the intervention was associated with statistically significant improvements in communication skills, specifically casual interaction (p=0.01) and purposeful interaction (p=0.03) as measured by the Measure of Participation in Conversation (MPC).^30^ Another study showed small statistically significant between-group differences favoring the intervention at end of treatment (3 months) on TBI dysexecutive and memory problems using the Behavioral Assessment of the Dysexecutive Syndrome scale (p=0.048) and Rivermead Behavioral Memory Test-profile (-2.55, 95% CI -4.97 to -0.13, p=0.04, n=31).^27^ The intervention included a heavy emphasis on providing information about TBI symptoms and on developing coping skills for patients and caregivers. A third study also reported positives changes in patient identified target symptoms as a result of the intervention (Cohen’s d=0.66, 95% CI 0.18 to 1.09).^28^

[underlined: Psychological symptoms.] One study examined care recipient psychological symptoms using the BSI and found no between-group difference related to intervention participation (Cohen’s d=0.24, p=0.24, n=96).^24^

#### TBI: Family Caregiver Outcomes

##### Quantitative Summary

A meta-analysis for 1 family caregiver-level outcome (caregiver psychological status) was conducted. This meta-analysis used data from 3 RCTs^25,26,28^ (254 patients) that evaluated problem-solving therapy with family caregivers^25,26^ and VIP.^28^ The number of contacts across interventions ranged from 8 to 12.

[underlined: Caregiver psychological symptoms.] Outcome measures included the Center for Epidemiological Studies-Depression scale (CES-D),^26,28^ the BSI-18,^25^ and the average of the HADS depression and anxiety scales to measure caregiver psychological symptoms^27^ (Figure 7). Results (296 patients) found no benefit of the intervention on caregiver psychological outcomes (SDM -0.26, 95% CI -0.57 to 0.05, I^2^=0.0, p=0.56).

Figure 7 Forest Plot of Psychological Symptoms for TBI Caregivers

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

We conducted a sensitivity analysis that omitted a study rated high ROB that used 8 sessions of group illness education targeting both family caregivers and care recipients^27^ (Figure 8). These more rigorous results found a positive effect of the interventions for family caregivers and patients on the overall functional status of patients with TBI (SDM -0.32, 95% CI -0.59 to -0.05, I^2^=0.0, Q=0.5, p=0.78). The SOE for this meta-analysis was rated as moderate.

Figure 8 Forest Plot of Sensitivity Analysis of Psychological Symptoms for TBI Caregivers

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

##### Qualitative Summary

Studies also reported changes in family caregiver quality of life, burden, and psychological symptoms. Adverse effects were not reported.

[underlined: Quality of life.] One study examined family caregiver quality of life at end of treatment using the Bakas Caregiving Outcomes Scale.^25^ The mean difference in scores between the intervention and treatment as usual control group was not statistically significant (mean difference 2.3, 95% CI -1.9 to 6.6, N=124). Another study used the Satisfaction with Life Scale (SWLS) to measure caregiver quality of life and found no effect over time (Cohen’s d= -0.14, p=0.52, n=67) at end of treatment (12 months).^26^

[underlined: Caregiver burden]. Three trials examined caregiver burden, but due to the high ROB of 1 study,^29^ we did not conduct a meta-analysis. Two studies used the Zarit Burden Scale to examine changes in family caregiver burden as a result of the intervention.^26,29^ One found no significant between-group effect over time (Cohen’s d=0.30, p=0.79) at end of treatment (12 months).^26^ The other study also found no within-group difference over time as a result of the intervention at end of treatment (22 weeks) (SMD 0.35, 95% CI -0.11 to 0.80.^29^ A third study used the burden subscale of the Modified Caregiver Appraisal measure to examine intervention effects on caregiver burden and found a statistically significant positive effect of the intervention on caregiver burden at end of treatment (4 months) (Cohen’s d=0.311, p=0.018, n=63).^35^ These effects are consistent in direction and magnitude of effect across all 3 studies.

#### TBI: Household Outcomes

##### Quantitative Summary

There were not enough studies that examined household-level outcomes to conduct a meta-analysis.

##### Qualitative Summary

Studies reported changes in family function, but household economic status was not examined as an outcome in any study.

[underlined: Family function.] One study with high ROB examined changes in family function as a result of the intervention.^24^ This study evaluated changes in the Family Assessment Device score between intervention and control groups and found no significant effect (Cohen’s d=0.25, p=0.23, n=62) at end of treatment.

### Detailed Findings for PTSD

Four RCTs (336 patients) evaluated patient-focused PTSD treatments with a family member involved or included and reported on family member outcomes. Three studies included Veteran participants.^31,33,34^ Mean participant age ranged from 33 to 47 years. All patients in the studies had a PTSD diagnosis, confirmed by a structured clinical interview (Clinician-Administered PTSD Scale),^31,33,34^ or supported by a symptom scale score (PTSD Symptom Scale).^32^ Patients were recruited from outpatient and community settings. Consistent with most literature on PTSD, the term “caregiver” was not utilized as this is a role more often recognized in support of patients with other disorders that more commonly fall under the “serious mental illness” category, requiring longer-term support. In 2 studies^33,34^ of couples’ treatment, the caregiver was defined as an intimate partner or cohabiting opposite-sex partner. In another study, 89% of family participants were spouses/partners and the remainder siblings or parents.^31^ One study did not describe the level or extent of family participation.^32^

Interventions varied substantially across studies and precluded meaningful meta-analyses. One 3-arm trial compared the effect of augmenting prolonged exposure (PE) therapy with a behavioral family therapy (BFT), a family-based skills-building intervention, for Veterans with chronic combat-based PTSD to PE alone and waitlist arms.^31^ Two studies compared couples-based therapies (CBCT-PTSD and structured approach therapy [SAT]) to waitlist^33^ or a family education control.^34^ Another study evaluated the effect of a multiple-family group intervention, Coffee and Family Education and Support (CAFES), education sessions aimed at increasing access to mental health care on a community population of Bosnian refugees living in the United States, via a 2-arm RCT.^32^ Interventions ranged from 9 to 16 sessions and were delivered in person over 12 weeks to 6 months. All interventions included an illness education component, 3 utilized formal therapies,^32–34^ 3 incorporated a skills-building strategy,^32,33^ and 1 used a social support strategy.^31^ Two companion studies^36,37^ reported on secondary analyses evaluating partner outcomes the CBCT-PTSD study.^33^ Table 5 summarizes findings for PTSD studies.

Table 5 Summary of Findings for PTSD Studies

Study Target | N Enrolled Veterans? | Study Design Comparison | Mean Age in Years (SD) % Female | Outcomes Reported | Overall Risk of Bias
Glynn, 1999^31^ Care recipient | 42 Yes | Cluster RCT Illness education vs waitlist or directed therapeutic exposure | [underlined: Caregiver] NR [underlined: Care recipient] 46.7 (3.1) %NR | [underlined: Caregiver] NR [underlined: Care recipient] Psychological (mood) Functional status (mental) Disease-specific (PTSD symptoms) | High
Monson, 2012^33^ Caregiver and care recipient | 40: 20 caregivers 20 care recipients Yes | RCT Illness education, therapeutic aspect and skills training vs waitlist | [underlined: Caregiver] 37.8 (11.3) 32% [underlined: Care recipient] 46.7 (3.1) 25% | [underlined: Caregiver] Psychological (mood) [underlined: Care recipient] Psychological (mood) Functional status (mental) Disease-specific (PTSD symptoms) [underlined: Aggregate] Family function (reported by both caregiver and care recipient) | Unclear
Sautter, 2015^34^ Caregiver and care recipient | 114: 57 caregivers 57 care recipients Yes | RCT Illness education, therapeutic aspect, and skills training vs PTSD family education | [underlined: Caregiver] 32.3 (7.8) 98% [underlined: Care recipient] 33.2 (6.6) 2% | [underlined: Caregiver] Psychological (mood) [underlined: Care recipient] Psychological (mood) Disease-specific (PTSD symptoms) [underlined: Aggregate] Family function (reported by both caregiver and care recipient) | Unclear
Weine, 2008^32^ Caregiver and care recipient | 197 care recipients; family was targeted also, but no reported demographics No | RCT Illness education, therapeutic aspect, social support, skills training and resource access vs treatment as usual | [underlined: Caregiver] NR [underlined: Care recipient] 37.7 (NR) 50.2% | [underlined: Caregiver] NR [underlined: Care recipient] Psychological (mood) Disease-specific (PTSD symptoms) Mental health service utilization | High

Abbreviations: NR=not reported; PTSD=posttraumatic stress disorder; RCT=randomized controlled trial; SD=standard deviation

#### PTSD: Care Recipient Outcomes

All studies reported patient outcomes in response to including family members in the intervention. Both couples-based interventions (SAT and CBCT-PTSD)^33,34^ showed consistent patterns of improved PTSD symptoms at the end of treatment as measured by clinician interview (mean difference on CAPS ranged 23.2 to 27.6) or patient-reported symptoms (mean difference on the PTSD Checklist ranged 8.4 to 11.8). Improved PTSD symptoms exceeded the threshold for clinically meaningful improvement. Other psychological symptoms, including patient-reported anxiety and depressive symptoms, showed a pattern of greater improvement with the intervention. Interpersonal relationships as reported by the patient also improved. One high ROB study found that the multiple-family group sessions increased the number of mental health visits among refugees with PTSD.^32^

#### PTSD: Family Caregiver Outcomes

Two studies^33,34^ (companions^36,37^) reported caregiver outcomes. Using structured approach therapy (SAT), neither self-reported depressive symptoms nor anxiety symptoms improved significantly compared to family education. In a secondary analysis of couples-based treatment for PTSD (CBCT-PTSD),^33^ partners who were in the distressed range at pretreatment reported significant improvements in depression and anxiety symptoms.^36^

#### PTSD: Household Outcomes

Only 2 studies reported limited family function outcomes.^33,34^ Interpersonal relationships as reported by the partner did not improve in either study (moderate SOE). In a secondary analysis of the study by Monson et al,^33,37^ CBCT-PTSD improved relational functioning posttreatment in partners who reported clinically-distressed levels of psychological functioning pretreatment.^37^ Household economic status was not examined as an outcome in any study.

### Quality of Evidence for Key Question 2

#### Risk of Bias for TBI Studies

We evaluated ROB for all TBI studies. The plots for the RCTs (n=6) and nonrandomized studies (n=2) are displayed in Figure 9. Of the 6 RCTs, 3 were considered to be low ROB,^23,25,28^ 1 was unclear ROB,^26^ and 2 were high ROB.^24,27^ Problems noted were lack of blinding of participants, personnel, and outcome assessors and incomplete reporting of outcome data.

Figure 9 Risk of Bias Ratings for TBI Studies

Two studies did not meet RCT study design criteria and were assessed as nonrandomized trials; both were considered to be high ROB.^29,30^ Problems included lack of allocation sequence generation, lack of adequately concealed allocation, and other risk. Of those studies, 1 had low ROB for similar baseline measurements, adequately addressed incomplete outcome measures, adequately prevented knowledge of allocated interventions during the study, and protection against contamination.^30^ Both nonrandomized studies were low ROB for selective outcome reporting. Note that although 1 study self-identified as an RCT, the investigation was funded over a 10-year period and during the first 5 years of funding, controls were not recruited.^29^ During the second 5 years, investigators were unable to recruit an equal number of control participants because many randomized to the control group were unwilling to wait 10 weeks before receiving the intervention, and for this reason we classified that study as nonrandomized.^29^

One study was an interrupted time series and was considered to have an unclear ROB.^22^ Three of 6 criteria were low ROB (prespecified intervention shape; free from selective outcome reporting; free from other risks), 2 of 6 criteria were graded as unclear ROB (intervention unlikely to affect data collection, incomplete outcome data adequately addressed), and 1 of 6 items was high ROB (intervention was independent of other changes).

#### Risk of Bias for PTSD Studies

Two PTSD studies were rated as unclear ROB^33,34^ and 2 as high ROB (Figure 10).^31,32^ Problems included unblinded or questionable blinding of outcome assessments in 3 studies and unclear allocation concealment and incomplete outcome data due to attrition concerns in 2 studies. Regarding the latter, significant attrition (35%) was acknowledged in 1 study as a result of the increasing burden of attending 16 additional weeks of family intervention after a full course of 18 twice-weekly prolonged exposure sessions.^31^ There was no evidence of selective reporting of study outcomes.

Figure 10 Risk of Bias Ratings for PTSD Studies