# Methods

## Topic Development

This evidence report was commissioned to describe the published literature on family caregiving interventions for patients with selected trauma-related illnesses, and to examine the effects of caregiver support programs on both caregivers and care recipients. The report is intended to inform the VA Caregiver Support Program and to identify future research needs to inform the program’s practices and policies.

The Key Questions (KQs) for this systematic review were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators, and consultation with content experts and key stakeholders at the VA Caregiver Support Program and the VA Office of Mental Health.

The final KQs were:

KQ 1 For which patient groups (ie, patients with posttraumatic stress disorder, traumatic brain injury, or polytrauma) that receive interventions that involve family members has the impact on care recipient outcomes been assessed?
KQ 2 What effects do programs or strategies that involve family caregivers have on care recipient and caregiver outcomes? Outcomes of interest include caregiver burden and psychological symptoms; care recipient functional status, psychological symptoms, quality-of-life indicators, disease-specific symptoms, independence, health care utilization; and family economic status, family functioning, and clinical eligibility for specific programs or services.

We followed a standard protocol for this review, and each step was pilot-tested to train and calibrate study investigators. The PROSPERO registration number is CRD42017053516.

## Search Strategy

In consultation with an expert librarian, we conducted searches of MEDLINE^®^ (via PubMed), CINAHL, and PsycINFO. We evaluated the bibliographies of systematic or nonsystematic reviews, and contacted content experts to identify additional relevant studies. We used a combination of MeSH keywords and selected free-text terms to search titles and abstracts. All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X7, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada). The exact search strategies used are in Appendix A.

## Study Selection

Using prespecified inclusion/exclusion criteria (Table 1), the titles and abstracts of articles included in existing reviews and identified through our primary search were reviewed independently by 2 reviewers for potential relevance to the KQs. Articles included by either reviewer underwent full-text screening. At the full-text screening stage, 2 independent reviewers were required to agree on a final inclusion/exclusion decision. Disagreements were resolved by discussion or by a third investigator. Articles meeting eligibility criteria were included for data abstraction. In brief, we included randomized trials and quasi-experimental studies evaluating a broad range of family caregiving interventions for patients with polytrauma, PTSD, or TBI that reported patient-centered outcomes. Interventions could be designed to support the caregiver or family member, or designed to support the patient with involvement or support from the family member (eg, couples therapy).

Table 1 Inclusion and Exclusion Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adults ≥18 years of age with any of the following conditions:; - Polytrauma (includes both physical only and physical + mental); - Posttraumatic stress disorder (PTSD); - Traumatic brain injury (TBI); Patients may be diagnosed with an eligible illness using criterion-based definitions (eg, DSM), validated screening/severity measures (eg, patient checklist), or clinical diagnosis. In addition to an eligible condition, patients must have functional cognitive, psychosocial, or other impairments that limit their ability to independently perform functions of daily life. | - Care recipients: <18 years of age or with developmental disorders (eg, autism), schizophrenia, bipolar disorder, schizoaffective disorder, psychotic disorder, or dementia; - Studies enrolling mixed samples with <70% of participants having an eligible condition; - Caregivers: Home-based care provided by a caregiver who does not have a preexisting relationship with care recipient
Interventions | Interventions that train family caregivers or support family caregiving or involvement by individuals who have a preexisting relationship (eg, family, friend) with the care recipient Interventions to support family caregiving may consist of 1 or more of the following:; - Caregiver training (eg, skills training to manage patient behavior); - Illness education; - Dyadic or family therapy; - Information about the health care system and community resources or social/emotional support (eg, mindfulness training, support groups, marital therapy); - Day-to-day practical support (eg, in-home respite care, instrumental support); - Financial assistance (eg, stipends that allow a family member to stay home); Interventions to train or support family caregivers may be delivered in person or by telephone. In-home respite care provides planned short-term and time-limited breaks for family caregivers of individuals with severe chronic illness in order to support and maintain the primary caregiving relationship. | - Caregiving interventions using remote technologies (eg, interactive voice response systems, medication reminders, smart homes, telehealth/videobased clinical appointments not for the purpose of caregiver training or vitals-monitoring systems); - Direct caregiving by a clinician or allied health care professional (eg, home health care service); - Peer support programs or therapy (eg, cognitive behavioral therapy) for the care recipient only; - Interventions or programs that occur primarily outside the home (eg, adult day services); as defined by the Department of Health and Human Services, adult day services provide an organized program in a community group setting to promote social, physical, and emotional well-being, with certification required for all adult day service providers
Comparators | Any comparator including waitlist, usual care, attention control, or active comparator | No comparator except for interrupted times series, which does not require a comparator
Outcomes | Care recipient primary outcomes:; - Functional status or health care quality of life—defined as global quality of life and further conceptualized to include functional status, including physical functioning (eg, activities of daily living), general psychological functioning (eg, psychological well-being), social functioning (eg, social well-being), and ability to live independently.; - Psychological outcomes including depressive symptoms or anxiety symptoms using standardized assessments; - Disease-specific symptoms (eg, patient checklist for PTSD); - Adverse effects; Caregiver primary outcomes:; - Caregiver burden (eg, Zarit Burden Scale); - Psychological outcomes including depressive symptoms or anxiety symptoms using standardized assessments; - Adverse effects; Family functioning (eg marital functioning, relationship quality); - Household economic status; - Care recipient health care utilization including outpatient, emergency department, inpatient, institutional, total | Studies that do not plan to report any included outcomes; however, studies that plan to report an included outcome but give cursory results (eg, p=NS) were included
Timing | Studies reporting outcomes at ≥28 days (approximately 1 month) following initiation of family caregiving intervention | Studies reporting outcomes at <28 days
Setting | Community settings | Institutional settings (eg, skilled nursing facility)
Study design | - Randomized controlled trials; - Cluster-randomized trials; - Nonrandomized cluster trials; - Controlled before-and-after studies with at least 2 intervention sites and 2 control sites; - Interrupted time series design | Case reports, case-series, and crosssectional studies and all studies without a comparator
Publication type | - English-language only; - Peer-reviewed articles; - Published from 1995 forward | - Non-English articles; - Abstracts only; - Letters to the editor; - Editorials; - Dissertations

## Data Abstraction

Data from published reports were abstracted into a customized DistillerSR database by one reviewer and overread by a second reviewer. Disagreements were resolved by discussion or by a third investigator. Data elements included descriptors to assess applicability, quality elements, intervention/exposure details, and outcomes. Key characteristics abstracted included patient descriptors, caregiver characteristics, intervention characteristics, comparator, and outcomes of interest (Appendix B). We abstracted outcomes at end of treatment and for the longest follow-up reporting comparative data. Multiple published reports from a single study were treated as a single study, prioritizing results based on the most complete and appropriately analyzed data. When critical data were missing or unclear in published reports, we requested supplemental data from the study authors. Key features relevant to applicability included the match between the sample and target populations (eg, age, community resources, or Veteran status).

## Categorization of the Interventions

Disease symptoms, treatment side effects, and consequences of disease progression are often the target of patient-centered interventions. Because both the interventions and targets of the interventions were unique and differed by condition, we used a general framework to categorize the interventions. We defined major intervention categories by grouping intervention components identified by existing reviews and that we expected might be related to the outcomes of interest within patients assessed for PTSD, TBI and polytrauma. We did not exclude any types of intervention categories. Our 5 major intervention categories were (1) skills training for caregivers (eg, change or manage patient behavior, communicate with care recipient), (2) education for caregivers (eg, illness education, tailored advice, planning for events), (3) interventions that provide support or counseling for family members related to their caregiving role (eg, counseling, stress management), (4) interventions to enhance support for caregivers (eg, social support), and (5) unique interventions with unique intervention targets.^16^ We categorized the intervention target as caregiver focused, patient focused, or dyadic.

## Quality Assessment

Quality assessment was done by the researcher abstracting or evaluating the included article; this initial assessment was overread by a second, highly experienced reviewer. Disagreements were resolved between the 2 reviewers or, when needed, by arbitration from a third reviewer.

We used the key quality criteria described by the Cochrane Effective Practice and Organization of Care Review Group for RCTs and nonrandomized studies.^17^ For RCTs, nonrandomized studies, and controlled before-after studies, these criteria are: adequacy of randomization and allocation concealment; comparability of groups at baseline; blinding; completeness of follow-up and whether incomplete data were addressed appropriately; protection against contamination; and selective outcome reporting. For interrupted time series studies, these criteria were: the independence of the intervention from other changes; prespecification of the shape of the intervention; whether the intervention was likely to affect data collection; blinded outcome assessment; whether incomplete data were addressed appropriately; and selective outcome reporting.^17^ We assigned a summary risk of bias (ROB) score (low, unclear, or high) to individual studies. Summary ROB was defined using Cochrane guidance: “low bias” as unlikely to alter the results seriously, “unclear bias” as raising some doubts about the results, and “high bias” as bias that may alter the results seriously.^18^

## Data Synthesis

We summarized the primary literature by abstracting relevant data from the eligible studies. For KQ 1, we described the breadth and types of studies conducted. We developed summary tables and figures to describe the literature, using number of studies over time, types of study designs, types of interventions, and descriptions of the types of outcomes reported. For KQ 2, summary tables describe the key study characteristics of the included studies such as study design, patient demographics (including age and condition), and details of the intervention and comparator. We categorized outcomes into caregiver outcomes (eg, caregiver burden), care recipient outcomes (eg, functional status), and household outcomes (eg, relationship quality, economic status). A table of outcome measures abstracted for this review is included in Appendix C.

We then determined the feasibility of completing a quantitative synthesis (ie, meta-analysis) to estimate summary effects. Feasibility depended on the volume of relevant literature, conceptual homogeneity of the studies, and completeness of results reporting. For all analyses, we focused on studies at low or moderate ROB. We aggregated outcomes when there were at least 3 studies with the same outcome, based on the rationale that 1 or 2 studies do not provide adequate evidence for summary effects. We planned to evaluate the consistency of effects by elements of the intervention, United States versus other countries, spouse versus non-spouse caregivers (or caregiver recipient relationship), and randomized versus nonrandomized design, but there were too few studies for these subgroup analyses.

Continuous outcomes were summarized using the standardized mean difference because studies used different measures for the same construct (eg, Patient Health Questionnaire and Beck Depression Inventory for depression severity). Although we focused on analyzing the follow-up measures, we used change from baseline in a few instances where baseline values differed substantially between the treatment arms. Standard deviation of change used the reported baseline and follow-up standard deviations and accounted for correlation between the baseline and follow-up measures. We used the Knapp Hartung approach to adjust the standard errors of the estimated summary coefficients in the random effects analyses.^19,20^ Sensitivity analyses omitted studies judged high ROB. We evaluated for statistical heterogeneity using visual inspection and Cochran’s Q and I^2^ statistics. Publication bias was not assessed using funnel plots because we did not have >10 studies in an analysis.

When quantitative synthesis was not feasible, we analyzed the data qualitatively. We gave more weight to the evidence from higher quality studies with more precise estimates of effect. A qualitative synthesis focuses on documenting and identifying patterns of the intervention across outcome categories. We analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## Rating the Body of Evidence

The strength of evidence for each KQ was assessed using the approach described in the Agency for Healthcare Research and Quality’s Methods Guide.^21^ We limited the Grading of Recommendations Assessment, Development and Evaluation (GRADE) ratings to primary outcomes identified by the stakeholder and Technical Expert Panel as critical to decision-making: functional status, disease-specific symptoms, caregiver burden, and adverse effects. In brief, this approach requires assessment of 4 domains: risk of bias, consistency, directness, and precision (Table 2).

Table 2 Strength of Evidence Required Domains

Domain | Rating | How Assessed
Quality (risk of bias) | Good Fair Poor | Assessed primarily through study design (randomized controlled trial vs observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect,” the overall range of effect sizes, and statistical measures of heterogeneity
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise | Based primarily on the size of the confidence intervals of effect estimates, the optimal information size, and considerations of whether the confidence interval crossed the clinical decision threshold for using a therapy

Additional domains were used when appropriate: coherence, dose-response association, impact of plausible residual confounders, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating was assigned after evaluation in the GRADE Pro software (https://gradepro.org/) and discussion by 2 reviewers as high, moderate, low, or very low strength of evidence. In some cases, high, moderate, or low ratings were impossible or imprudent to make. In these situations, a grade of insufficient was assigned. This 4-level rating scale consists of the following definitions:

- High—High confidence that the true effect lies close to that of the estimate of the effect.
- Moderate—Moderate confidence in the effect estimate. The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low—Limited confidence in the effect estimate. The true effect may be substantially different from the estimate of the effect.
- Very low—Very little confidence in the effect estimate. The true effect is likely to be substantially different from the estimate of effect.

## Peer Review

This report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix D.