# Evidence Report

## Introduction

Family members perform a significant service caring for Veterans with severe physical, mental, and cognitive impairments. In the United States, 1.1 million family members provide care for Veterans who served in the military since September 11, 2001,^1^ a population characterized by high rates of physical injury, including musculoskeletal problems and associated pain, polytrauma,^2^ traumatic brain injury (TBI), and traumatic mental health conditions such as posttraumatic stress disorder (PTSD). Beyond the most commonly reported tasks of helping with essential daily activities, such as grocery shopping or managing finances, and helping the Veteran cope with stressful situations, caregivers fill an important role in helping Veterans engage with their health care.^1^ Depending on the injuries and health conditions, for some families the need for intensive family caregiving support can last for decades.^1^ Further, caregiving can have negative implications for caregiver physical and mental health,^3,4^ employment,^5,6^ and financial security.^7–9^ Family caregivers of post-9/11 Veterans differ from the general population of caregivers in that they are younger and thus more likely to be actively managing work and raising children while performing caregiving tasks. Systematic support and training that takes into account individual contexts, preferences, and needs may help family caregivers to facilitate Veteran recovery processes at home.^10^

Generally, there is a need for health care systems to recognize the role that family caregivers play and for evidence-based strategies to include them as part of the health care team.^10,11^ Such support may be critical not only to optimize the well-being and functioning of family members, but also to ensure that individual recovery processes are supported consistently and with high-quality care from the health care team and family members in the home. In recognition of the role that family caregivers play in helping Veterans in their recovery process, the US Congress signed into law the Caregivers and Veterans Omnibus Health Services Act of 2010, which established the Program of Comprehensive Assistance for Family Caregivers (PCAFC) in the Department of Veterans Affairs. This program provides unprecedented support for family caregivers of Veterans seriously injured during military service on or after September 11, 2001. Covered services include a financial stipend, access to health care, skills training, education about VA resources and services, respite care, and travel support. Demand for the program has far exceeded expectations, with more than 32,000 caregivers approved since May 2011.

Systematic reviews have shown that some caregiver supportive services can improve caregiver outcomes, primarily by reducing caregiver burden and mental distress,^12,13^ and improve care recipient function.^13^ Yet this research has focused most frequently on care recipients with cognitive or memory disorders and other illnesses such as cancer.^12^ Given the demand for PCAFC services, there is a need to better understand the impact of caregiver interventions on care recipient populations with long-term, disabling conditions that are common among Veterans, including PTSD, TBI, and polytrauma. In particular, the number of Veteran service users in 2015 with a PTSD diagnosis represented 10% of all users (ie, 600,000 of 5.7 million users), and very little is known about how to best support these Veterans through family engagement.^14^ It is possible that intervention mechanisms operate differently among these populations due to their life stage, duration of expected caregiving needs, and care recipient symptoms.

### Who are the Family Caregivers?

A family caregiver may be defined as “any relative, partner, friend or neighbor who has a significant personal relationship with, and provides a broad range of assistance for, an older person or an adult with a chronic or disabling condition.”^15^ These individuals may be primary or secondary caregivers and live with, or separately from, the person receiving care.

In the mental health caregiving literature, particularly among younger care dyads, family members frequently do not identify themselves as a “caregiver.” This reflects the reality that there is no perfect term. Other terms that are relevant are “informal caregivers” to indicate this care is not from trained, health care professionals and is typically unpaid. Other terms are “care partners,” “companions,” “close others,” and “carers.” For the remainder of this paper we use the term “family caregiver” to refer more generically to persons who either provide unpaid hands-on care or help navigate the health care system.

### Purpose of the Review

This evidence synthesis describes the volume of published literature evaluating family caregiving interventions for patients with polytrauma, TBI, and PTSD and the effects of these interventions and strategies on caregiver and care recipient (patient) outcomes. Our eligibility criteria are purposefully broad to include interventions that focus exclusively on caregivers and those that focus on patients but incorporate a family member or caregiver. For the purposes of this report, we use the term “family caregiving interventions” to mean interventions that are patient-focused and involve caregivers or families of patients (care recipients) with TBI, PTSD, and polytrauma. We anticipate the report will be used by the VA Caregiver Support Program to refine or expand existing educational opportunities, for example training that is provided as part of the eligibility process, for this important and prevalent population by shedding light on characteristics of effective caregiver support programs and corresponding characteristics of the populations who benefit. Further, providing a comprehensive inventory of the common measures that others have used to quantify recovery, emotional well-being, and other outcomes of function will advance our understanding of how to evaluate caregiver interventions among this population of individuals with trauma-associated injury.