# APPENDIX C Outcome Measures Table

This table includes the most commonly used measures to assess the outcomes of interest in our systematic review. It is not a complete listing of all outcomes assessed in these studies. For full study citations, please refer to the report’s main reference list.

Outcome Measures Used in Eligible Studies

Domain | Measure | Description | Scoring Range
Caregiver burden | Bakas Caregiving Outcomes Scale^25^ | 15-item, 7-point scale measures change in social function, emotional well-being, and physical health related to caregiving | Range 15-105, higher is better changes in outcomes
Caregiver burden | Modified Caregiver Appraisal scale^35^ | 28-item, 5-point scale, measures positive and negative perception of the caregiver role | Range 28-140; higher is more positive feelings toward caregiving role
Caregiver burden | Zarit Burden Scale^26,29^ | 22-item, 5-point scale, measures personal strain and role strain | Range 0-88, higher is worse outcome
Family function | Dyadic Adjustment Scale^31,33,34^ | 32-item, 5-point scale, self-report measure of relationship satisfaction | Range 0-160; >98 is criteria for relationship satisfaction
Family function | Experiences in Close Relationship-Revised Scale^34^ | 36-item, 7-point scale, measuring insecurity/security about availability and attunement of partners, and the extent that people are uncomfortable being close to others | Range 36-252, higher is greater severity 18 items measure attachment-related anxiety; 18 items measure attachment-related avoidance
Family function | Family Assessment Device^24^ | 60-item, 4-point scale measures structural, organizational, and transactional characteristics of families | Range 60-240; higher is worse functioning
Functional status | Community Integration measure (CIM)^24^ | 10-item, 5-point scale, client-centered survey of perceived connections of individuals with TBI and the community in 4 dimensions (general assimilation, support, occupation, and independent living) | Range 10 to 50; higher is higher integration
Functional status | Community Reintegration Scale (CRIS)^28^ | Questionnaire to identify and prevent community reintegration problems for Veterans. It consists of 147 items across 3 subscales: Extent of Participation, Perceived Limitations in Participation, and Participation Satisfaction. | Range NR; this study used 15 items from the Extent of Participation study scored either 1-6, 1-3, or 0-3
Functional status | Functional Independence Measure (FIM)^27^ | 18-item, 5-point scale measures disabilities in performing basic life activities and the need for assistance and the burden of care as perceived by the carer | Range 13-91 for first 13 items (motor function); range 5-35 for last 5 items (cognitive function); higher is better on both subscales
Functional status | Patient Competency Rating Scale (PCRS)^28^ | 30-item, 5-point scale to evaluate self-awareness and degree of difficulty performing a variety of tasks following TBI | Range 30-150; higher is better function in both patient and caregiver form
Psychological Symptoms | Beck Depression Inventory-II^33^ | 21-item, 4-point scale (0-3) self-report measuring depression symptoms in past week | 0-63, higher score is worsening symptoms
Psychological Symptoms | Center for Epidemiological Studies Depression Scale (CESD)^32,33^ | 20-item, 4-point scale (0-3), self-report of depressive symptoms over the past week | 0-60, higher score is worsening symptoms
Psychological Symptoms | BSI^24^ | 53-item, 5-point scale (0-4), self-report for participants to rate the extent to which they have been bothered in the past week by various symptoms | Range 0-212 but reported as T score, higher score is worsening symptoms
Psychological Symptoms | General Well Being Scale^22^ | 22-item, 5-point scale that measures perceived well-being on 6 dimensions, anxiety, depressed mood, positive well-being, self-control, general health, and well-being | Range (original) 0-110, (revised) 22-132; higher is better well-being
Psychological Symptoms | Hospital Anxiety and Depression Scale (HADS)^27^ | 14-item, 4-point scale, measuring self-reported anxiety and depressive symptoms over the past week | Range 0-42, higher scores worse
Psychological Symptoms | State-Trait Anger Expression Inventory^33^ | 10-item, 4-point scale, trait subscale measures how often angry feelings are experienced over time 18-item, 5-point scale, anger expression (state) subscale assesses the intensity of anger as an emotional state at a particular time | Range 10-40, higher is greater severity Range 0-72, higher is greater severity
Psychological Symptoms | State-Trait Anxiety Inventory^33^ | 20-item, 4-point scale (1-4) measures state (in the moment) anxiety; 20-item, 4-point scale (1-4) measures trait (over time) anxiety; 2 scales reported separately | Range 20-80; higher is greater severity Range 20-80; higher is greater severity
PTSD symptoms | Clinician-Administered PTSD Scale^31–34^ | Semi-structured interview measuring DSM*-based PTSD symptoms | Range 0-136, higher is greater severity; 10 points indicates a clinically significant change
PTSD Symptoms | Impact of Events Scale^31^ | 15-item, 6-point scale (0-5), self-reports measuring re-experiencing and avoidance-numbing dimensions of PTSD | Range 0-75, higher is greater severity
PTSD Symptoms | Mississippi Scale for Combat-Related PTSD^31^ | 35-item, 5-point scale (1-5) self-reports measuring PTSD symptoms | Range 35-175, higher is greater severity
PTSD Symptoms | PTSD Checklist^33,34^ | 17-item, 9-point scale (0-8) self-reports measuring PTSD symptoms (civilian and military versions) | Range 0-136, higher is greater severity; 10 points indicates a clinically significant change
PTSD Symptoms | PTSD Symptom Scale^32^ | 22-item, 5-point scale (0-4) self-reports measuring PTSD symptoms (2-item measure symptom onset and duration) | Range 0-88, higher is greater severity
Quality of life | Life Satisfaction Survey^25^ | 17-item measures quality of life as perceived by the patient | Total score range 0-100, higher is better satisfaction
Quality of life | Short Form-36 (SF-36)^23^ | 36-item, 5-point scale, self-report on 8 dimensions | Range 0-100, reported as subscales; higher is better
Quality of life | Perceived Quality of Life (PQOL)^23^ | 19-item, 11-point response scale plus single global item on happiness, evaluates satisfaction with areas of functional status | Range 0-190; higher is more satisfied
Quality of life | Satisfaction with Life Scale (SWLS)^26^ | 5-item, 7-point scale that measures global cognitive judgement of one’s life satisfaction | Range 1-35, higher is better quality of life
Quality of life | Social Adjustment Scale-Self report^31^ | 54 items measure health status across 6 dimensions: work; social and leisure; relations with extended family; marital role; parental role; membership in family unit | Range is NR as each subscale is scored separately
TBI symptoms | Behavioral Assessment Dysexecutive Syndrome scale (BADS)^27^ | 6 subscales; measures everyday problems associated with dysexecutive syndrome (in planning, organization, problem solving, attention, etc) | Range 0-24; higher is better
TBI symptoms | Measure of Participation in Conversation (MPC)^30^ | 2 subscales, 9-point scale (measured on 0.5 between 0 and 4), measures patient’s ability to participate in the interactional and transactional elements of conversation | Range 0-4 (by half-point increments), higher is better participation in conversation
TBI symptoms | Rivermead Behavioral Memory Test-profile^27^ | Measures aspect of visual, verbal, recall, recognition, immediate and delayed everyday memory | Information on scoring NR