# APPENDIX B Intervention Tables

This appendix contains an Interventions Components Table and an Interventions Details Table. For full study citations, please refer to the report’s main reference list.

Intervention Components Table

Study | Brief Description | Illness education | Financial Assistance | Therapeutic Aspect | Social Support | Skills Training | “Other” Component | Outcome timing
Traumatic brain injury
Acorn, 1995^22^ | [underlined: Illness education & emotional support:] Three 10-hour group sessions covering 10 modules | × | – | – | × | – | – | End of treatment, 1 month, and 2 months posttreatment
Bell, 2005^23^ | [underlined: Illness education & resource access]: 7 telephone sessions over 9 months using motivational interviewing for problem-solving | × | – | – | – | – | Helped access resources (ie, mailed materials or made referrals as appropriate) | 1 year post-hospitalization
Hanks, 2012^24^ | [underlined: Illness education, social support, & resource access]: 17 sessions where mentor and mentee met and/or talked via phone, tapering from weekly to monthly over 1 year | × | – | – | × | – | Discussions around post-TBI issues and help to access community resources | End of treatment (12 months)
Kreutzer, 2015^29^ | [underlined: Illness education, skills training, & homework]: 5 sessions over 10 weeks designed to enhance family functioning | × | – | – | – | × | Homework; worksheets to complete between sessions | End of treatment (10 weeks) and 22 weeks
Powell, 2016^25^ | [underlined: Illness education & skills training]: 1-on-1 phone calls with patient and/or family to teach problemsolving on 12 topics related to TBI | × | – | – | – | × | – | 6 months
Rivera, 2008^26^ | [underlined: Therapeutic aspects & skills training]: provided to caregivers in 4 in-home sessions and 8 phone calls over 1 year | – | – | × | – | × | – | 16, 32, and 52 weeks
Sinnakaruppan, 2005^27^ | [underlined: Illness education, skills training, & handouts]: Eight 2.5-hour, in-person sessions, conducted in separate groups for care givers and recipients | × | – | – | – | × | Handouts to complement the training sessions | End of treatment and 3 months
Togher, 2013^30^ (Companion articles: Togher, 2012^60^; Togher, 2016^61^; Sim, 2013^62^) | [underlined: Illness education, therapeutic aspect, & skills training]: 10 weeks of both group and individual sessions for either care recipients alone or with their communication partners | × | – | ×^a^ | – | × | – | End of treatment (10 weeks) and 6 months
Winter, 2016^28^ Moriarty, 2016^35^ | [underlined: Illness education, skill training, & resource] access: 6 in-home visits and 2 phone calls with family member over 4 months targeting family function, environment | × | – | – | – | × | Help with access to community and other resources | 4 months
Posttraumatic stress disorder
Glynn, 1999^31^ | [underlined: Illness education]: 16 sessions testing a familybased skills-building program to augment 18 exposure treatments for veterans with PTSD | × | – | – | - | – | | End of treatment and 6 month
Monson, 2012^33^ (Companion articles: Shnaider, 2014^36^; Shnaider, 2015^37^) | [underlined: Illness education, therapeutic aspect, & skills training]: delivered in a couples therapy format; consists of 15 sessions organized into 3 phases with in- and out-of-session exercises | × | - | × | - | × | - | Mid-treatment (4 weeks) and end of treatment (12 weeks)
Sautter, 2015^34^ | [underlined: Illness education, therapeutic aspect, & skills training]: 12 weekly, in-person, conjoint sessions, and exposure treatments for Veterans with PTSD and their cohabiting partners | × | – | × | – | × | – | 3, 6, 9, 12 weeks, and 12 week follow-up (24 weeks)
Weine, 2008^32^ | [underlined: Illness education, therapeutic aspect, social support, skills training, & resource access]: 9 multifamily group sessions over 16 weeks | × | – | × | × | × | Help with access to mental health resources | End of treatment, 6, 12, and 18 months
Totals | | 12 (92%) | 0 | 5 (38%) | 3 (23%) | 9 (69%) | 7 (54%)

a This study did not employ a therapist or name the intervention as a type of therapy per se, but the description of the communication strategies contained aspects of the therapeutic process.

Abbreviations: CBT=cognitive behavioral therapy; PTSD=posttraumatic stress disorder; TBI=traumatic brain injury

Intervention Details Table

Study | Planned frequency and duration | Number of sessions delivered | Discipline(s) providing service | Intervention Delivery Type | Intervention Delivery Mode | Target
Traumatic brain injury
Acorn, 1995^22^ | 3 weekend sessions, 10 hours each weekend | NR | Nurse | Group | In person | Caregiver only
Bell, 2005^23^ | 7 phone calls at 2, 4 weeks, and 2, 3, 5, 7, and 9 months post-discharge lasting 30-45 minutes | [underlined: Recipients] Median: 4 calls (IQR: 2 to 6) lasting 34 min (IQR: 20 to 55) [underlined: Caregivers] Median: 4.5 calls (IQR:2 to 6) lasting 30 min (IQR: 15 to 55) | “Research care manager”–no training in brain injury or advanced degree | One-on-one | Phone, written | Caregiver and care recipient
Hanks, 2012^24^ | 17 sessions tapering from 1 per week to 1 per month; duration was not planned | 5.4 (4.0); mostly by phone; duration ranged 5 min to >1 hour | Peer mentor (hired as contingent employee) | One-on-one | In person, phone, web | Care recipient
Kreutzer, 2015^29^ | Five 2-hour sessions within 10-week period | NR | Psychologist | One-on-one | In person | Care recipient
Powell, 2016^25^ | 8-10 calls, once every 2 weeks for 5 weeks | 7-10 calls (n=41); 1-6 calls (n=30); no calls (n=6) | Social worker | One-on-one | Phone, written | Care recipient
Rivera, 2008^26^ | 12 sessions: 4 in-person, 8 via phone | NR | PhD in administration and relevant volunteer experience, but never employed as a counselor | One-on-one | In person, phone | Care recipient
Sinnakaruppan, 2005^27^ | 8 sessions (4 for caregivers, 4 for recipients) [duration NR] | NR | Psychologist | Group | In person, written | Caregiver and care recipient
Togher, 2013^30^ (Companion articles: Togher, 2012^60^; Togher, 2016^61^; Sim, 2013^62^) | 2.5-hour group session and 45-60 minute individual session every week for 10 weeks | 8 sessions; had to attend 80% for data to be analyzed | Speech pathologists | Group and one-on-one | In person | Caregiver and care recipient
Winter, 2016^28^ Moriarty, 2016^35^ | 6 home visits lasting 1-2 hours each; 2 phone calls | Mean 4.67 visits (no SD given) | Occupational therapist | One-on-one | In person, phone | Caregiver and care recipient
Posttraumatic stress disorder
Glynn, 1999^31^ | 18 sessions of twice-weekly direct therapeutic exposure followed by 16 sessions of behavioral family therapy; frequency decreasing to monthly over 6 months | 17.6 (SD 3.3) for direct therapeutic exposure; 15.6 (SD 2.2) for behavioral family therapy; duration not given | Psychologist | One-on-one | In person | Caregiver and care recipient
Monson, 2012^33^ (Companion articles: Shnaider, 2014^36^; Shnaider, 2015^37^) | 15 sessions over 16 weeks starting thrice weekly for phases 1 & 2; weekly for phase 3; duration of each session NR | NR | Psychologist or doctoral level psychology student | One-on-one | In person | Caregiver and care recipient
Sautter, 2015^34^ | 12 sessions of weekly conjoint therapy and education; 3 additional weekly sessions if needed | Mean 10.31 (no SD given) | Doctoral-level clinicians and master’s level social workers | One-on-one | In person | Caregiver and care recipient
Weine, 2008^32^ (Companion article: Weine, 2005^63^) | 9 sessions over 16 weeks | Mean 6.8 (no SD given); 83% of “engaged” families attended ≥5 sessions | Bosnian refugee with experience doing group work (teacher, nurse, etc) | Group | In person | Caregiver and care recipient

Abbreviations: CBT=cognitive behavioral therapy; IQR=interquartile range; NR=not reported; PTSD=posttraumatic stress disorder; SD=standard deviation; TBlHxaumatic brain injury