# APPENDIX A Search Strategies

PubMed: 12/19/2016

Set | Terms | Results
#1 | “Combat Disorders”[Mesh] OR “Stress Disorders, Post-Traumatic”[Mesh] OR “Post Traumatic Stress Disorder”[tiab] OR “Post Traumatic Stress Disorders”[tiab] OR “Posttraumatic Stress Disorder”[tiab] OR “Posttraumatic Stress Disorders”[tiab] OR “PTSD”[tiab] OR “Post Traumatic Neuroses”[tiab] OR “Posttraumatic Neuroses”[tiab] OR “Psychotic Disorders”[Mesh] OR “Psychotic Disorder”[tiab] OR “Psychosis”[tiab] OR “Psychoses”[tiab] OR “Schizoaffective Disorder”[tiab] OR “Schizoaffective Disorders”[tiab] OR “Schizophreniform Disorders”[tiab] OR “Schizophreniform Disorder”[tiab] OR “Craniocerebral Trauma”[Mesh] OR “traumatic brain”[tiab] OR “brain trauma”[tiab] OR TBI[tiab] OR “intracranial injury”[tiab] OR “intracranial injuries”[tiab] OR “traumatic encephalopathy”[tiab] OR “posttraumatic encephalopathy”[tiab] OR “post traumatic encephalopathy”[tiab] OR “cerebral trauma”[tiab] OR (“blast—induced”[tiab] AND brain[tiab]) OR “Multiple Trauma”[Mesh] OR “multiple trauma”[tiab] OR “multiple traumas”[tiab] OR “multiple wound”[tiab] OR “multiple wounds”[tiab] OR “multiple injury”[tiab] OR “multiple injuries”[tiab] OR Polytrauma[tiab] OR “Poly trauma”[tiab] OR Polytraumas[tiab] OR “Poly traumas”[tiab] OR Polytraumatised[tiab] OR “Poly traumatized”[tiab] OR “Polytraumatic”[tiab] OR “Poly traumatic”[tiab] OR “serious mental illness”[tiab] OR ((“Veterans Health”[Mesh] OR “Veterans”[Mesh] OR veterans[tiab] OR veteran[tiab] OR “Disabled Persons”[Mesh] OR “Trauma and Stressor Related Disorders”[Mesh]) AND (“Cognition Disorders”[Mesh] OR “Intellectual Disability”[Mesh] OR “cognition disorder”[tiab] OR “cognition disorders”[tiab] OR “Cognitive impairment”[tiab] OR “cognitively impaired”[tiab] OR “Functional impairment”[tiab] OR “functionally impaired”[tiab])) | 268,090
#2 | (“Home Nursing”[Mesh] OR “home nursing”[tiab] OR “home-based”[tiab] OR “Nonprofessional Home Care”[tiab] OR “Non-Professional Home Care”[tiab] OR “informal care”[tiab] OR “informal caregiver”[tiab] OR “informal caregivers”[tiab] OR “informal carer”[tiab] OR “informal carers”[tiab] OR “informal caregiving”[tiab] OR “informal caretaker”[tiab] OR “informal caretakers”[tiab] OR “informal social support”[tiab] OR “family-inclusive”[tiab]) OR ((“Patient Care”[Mesh] OR “Caregivers”[Mesh] OR caregiver[tiab] OR caregivers[tiab] OR carer[tiab] OR carers[tiab] OR caregiving[tiab] OR “care giving”[tiab]) AND (“custodial”[tiab] OR “domiciliary”[tiab] OR “respite”[tiab] OR “home”[tiab] OR “Community Dwelling”[tiab] OR “Social Environment”[Mesh:NoExp] OR “Social Support”[Mesh] OR “Psychosocial Support”[tiab])) OR ((“Patient Care”[Mesh] OR “Caregivers”[Mesh] OR caregiver[tiab] OR caregivers[tiab] OR carer[tiab] OR carers[tiab] OR caregiving[tiab] OR “care giving”[tiab]) AND (“Family”[Mesh] OR family[tiab] OR families[tiab] OR relatives[tiab] OR stepfamily[tiab] OR stepfamilies[tiab] OR kinship[tiab] OR friend[tiab] OR “Marriage”[Mesh] OR marriage[tiab] OR married[tiab] OR wedded[tiab] OR “spouses”[Mesh] OR spouse[tiab] OR spouses[tiab] OR spousal[tiab] OR wife[tiab] OR wives[tiab] OR husband[tiab] OR husbands[tiab] OR girlfriend[tiab] OR boyfriend[tiab] OR “domestic partner”[tiab] OR “domestic partners”[tiab] OR “domestic partnership”[tiab] OR “domestic partnerships”[tiab] OR “interpersonal relations”[MeSH Terms] OR “interpersonal relations”[tiab] OR “intimate partner”[tiab] OR “intimate partners”[tiab] OR “intimate partnership”[tiab] OR “intimate partnerships”[tiab] OR “intimate relationship”[tiab] OR cohabitate[tiab] OR cohabitant[tiab] OR cohabitants[tiab] OR parent[tiab] OR parents[tiab] OR parental[tiab] OR stepparent[tiab] OR stepparents[tiab] OR mother[tiab] OR mothers[tiab] OR moms[tiab] OR Father[tiab] OR fathers[tiab] OR dads[tiab] OR stepfather[tiab] OR stepfathers[tiab] OR son[tiab] OR sons[tiab] OR stepson[tiab] OR stepsons[tiab] OR child[tiab] OR children[tiab] OR daughter[tiab] OR daughters[tiab] OR stepdaughter[tiab] OR stepdaughters[tiab] OR uncle[tiab] OR uncles[tiab] OR aunt[tiab] OR aunts[tiab] OR sibling[tiab] OR siblings[tiab] OR sister[tiab] OR sisters[tiab] OR stepsister[tiab] OR stepsisters[tiab] OR brother[tiab] OR brothers[tiab] OR stepbrother[tiab] OR stepbrothers[tiab] OR cousin[tiab] OR cousins[tiab] OR grandparent[tiab] OR grandparents[tiab] OR grandmother[tiab] OR grandmothers[tiab] OR grandfather[tiab] OR grandfathers[tiab])) | 208,176
#3 | #1 AND #2 | 6,573
#4 | #3 NOT ((“Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh]) NOT “Adult”[Mesh]) AND English[lang] | 4,257
#5 | (systematic[sb] OR “Systematic Review”[tiab] OR “Umbrella Review”[tiab] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “randomized controlled trial”[ptyp] OR “controlled clinical trial”[ptyp] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR “Comparative Study”[ptyp] OR “Controlled Clinical Trial”[ptyp] OR nonrandom[tiab] OR “non-random”[tiab] OR nonrandomized[tiab] OR “non-randomized”[tiab] OR nonrandomised[tiab] OR “non-randomised”[tiab] OR quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasi-random*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab] OR (controlled[tiab] AND (trial[tiab] OR study[tiab])) OR “prepost”[tiab] OR “posttest”[tiab] OR “post-test”[tiab] OR pretest[tiab] OR pretest[tiab] OR (“time series”[tiab] AND interrupt[tiab]) OR (“time points”[tiab] AND (multiple[tiab] OR one[tiab] OR two[tiab] OR three[tiab] OR four[tiab] OR five[tiab] OR six[tiab] OR seven[tiab] OR eight[tiab] OR nine[tiab] OR ten[tiab] OR month[tiab] OR monthly[tiab] OR day[tiab] OR daily[tiab] OR week[tiab] OR weekly[tiab] OR hour[tiab] OR hourly[tiab])) OR (before[tiab] AND after[tiab]) OR (before[tiab] AND during[tiab])) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) | 3,291,302
#6 | #4 AND #5 | 1,325

CINAHL: 12/19/2016

Set | Terms | Results
S1 | (MH “Stress Disorders, Post-Traumatic+”) OR “combat disorders” OR “Post Traumatic Stress Disorder” OR “Post Traumatic Stress Disorders” OR “Posttraumatic Stress Disorder” OR “Posttraumatic Stress Disorders” OR “PTSD” OR “Post Traumatic Neuroses” OR “Posttraumatic Neuroses” OR (MH “Psychotic Disorders+”) OR “Psychotic Disorder” OR “Psychosis” OR “Psychoses” OR “Schizoaffective Disorder” OR “Schizoaffective Disorders” OR “Schizophreniform Disorders” OR “Schizophreniform Disorder” OR (MH “Head Injuries+”) OR “traumatic brain” OR “brain trauma” OR TBI OR “intracranial injury” OR “intracranial injuries” OR “traumatic encephalopathy” OR “posttraumatic encephalopathy” OR “post traumatic encephalopathy” OR “cerebral trauma” OR (“blast—induced” AND brain) OR (MH “Multiple Trauma+”) OR “multiple trauma” OR “multiple traumas” OR “multiple wound” OR “multiple wounds” OR “multiple injury” OR “multiple injuries” OR Polytrauma OR “Poly trauma” OR Polytraumas OR “Poly traumas” OR Polytraumatised OR “Poly traumatized” OR “Polytraumatic” OR “Poly traumatic” OR “serious mental illness” OR (((MH “Veterans+”) OR veterans OR veteran OR (MH “Disabled+”)) AND ((MH “Adjustment Disorders+”) OR (MH “Cognition Disorders+”) OR (MH “Intellectual Disability+”) OR “cognition disorder” OR “cognition disorders” OR “Cognitive impairment” OR “cognitively impaired” OR “Functional impairment” OR “functionally impaired”)) | 145,641
S2 | (MH “Home Nursing+”) OR “home nursing” OR “home-based” OR “Nonprofessional Home Care” OR “Non-Professional Home Care” OR “informal care” OR “informal caregiver” OR “informal caregivers” OR “informal carer” OR “informal carers” OR “informal caregiving” OR “informal caretaker” OR “informal caretakers” OR “informal social support” OR “family-inclusive” OR (((MH “Patient Care+”) OR (MH “Caregivers+”) OR caregiver OR caregivers OR carer OR carers OR caregiving OR “care giving”) AND (custodial OR domiciliary OR respite OR home OR “Community Dwelling” OR (MH “Social Environment+”) OR (MH “Support, Pyschosocial+”) OR “Psychosocial Support”)) OR (((MH “Patient Care+”) OR (MH “Caregivers+”) OR caregiver OR caregivers OR carer OR carers OR caregiving OR “care giving”) AND ((MH “Family+”) OR family OR families OR relatives OR stepfamily OR stepfamilies OR kinship OR friend OR (MH “Marriage+”) OR marriage OR married OR wedded OR (MH “Spouses+”) OR spouse OR spouses OR spousal OR wife OR wives OR husband OR husbands OR girlfriend OR boyfriend OR “domestic partner” OR “domestic partners” OR “domestic partnership” OR “domestic partnerships” OR (MH “Interpersonal Relations+”) OR “interpersonal relations” OR “intimate partner” OR “intimate partners” OR “intimate partnership” OR “intimate partnerships” OR “intimate relationship” OR cohabitate OR cohabitant OR cohabitants OR parent OR parents OR parental OR stepparent OR stepparents OR mother OR mothers OR moms OR Father OR fathers OR dads OR stepfather OR stepfathers OR son OR sons OR stepson OR stepsons OR child OR children OR daughter OR daughters OR stepdaughter OR stepdaughters OR uncle OR uncles OR aunt OR aunts OR sibling OR siblings OR sister OR sisters OR stepsister OR stepsisters OR brother OR brothers OR stepbrother OR stepbrothers OR cousin OR cousins OR grandparent OR grandparents OR grandmother OR grandmothers OR grandfather OR grandfathers)) | 223,352
S3 | S1 AND S2 | 14,233
S4 | ((MH “Randomized Controlled Trials+”) OR (MH “Systematic Review+”) OR (MH “Meta Analysis+”)) OR TI (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomization” OR “randomised” OR “randomisation” OR “randomly” OR “trial” OR “groups” OR “comparative study” OR “nonrandom” OR “non-random” OR “nonrandomized” OR “non-randomized” OR “nonrandomised” OR “non-randomised” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study)) OR “pre-post” OR “posttest” OR “post-test” OR “pretest” OR “pre-test” OR (“time series” AND “interrupt”) OR ((“time points”) AND (multiple OR one OR two OR three OR four OR five OR six OR seven OR eight OR nine OR ten OR month OR monthly OR day OR daily OR week OR weekly OR hour OR hourly)) OR (before AND after) OR (before AND during) OR “systematic review” OR “Umbrella Review” OR “meta-analysis” OR “meta-analyses” OR “meta-synthesis” OR “meta-syntheses”) OR AB (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomization” OR “randomised” OR “randomisation” OR “randomly” OR “trial” OR “groups” OR “comparative study” OR “nonrandom” OR “non-random” OR “nonrandomized” OR “non-randomized” OR “nonrandomised” OR “nonrandomised” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study)) OR “pre-post” OR “posttest” OR “post-test” OR “pretest” OR “pre-test” OR (“time series” AND “interrupt”) OR ((“time points”) AND (multiple OR one OR two OR three OR four OR five OR six OR seven OR eight OR nine OR ten OR month OR monthly OR day OR daily OR week OR weekly OR hour OR hourly)) OR (before AND after) OR (before AND during) OR “systematic review” OR “Umbrella Review” OR “meta-analysis” OR “meta-analyses” OR “meta-synthesis” OR “meta-syntheses”) AND (PT journal article) | 513,457
S5 | S4 NOT PT (Abstract OR Book OR Book Chapter OR Book Review OR Case Study OR Commentary OR Doctoral Dissertation OR Editorial OR Letter OR Masters Thesis OR Pamphlet OR Pamphlet Chapter OR Poetry) NOT TI (Editorial OR Letter OR “Case Report” OR Comment) | 484,282
S6 | S3 AND S5 | 2,138
S7 | S6 Limiters - Language: English; Age Groups: All Adult | 1,367

PsycINFO: 12/19/2016

Set | Terms | Results
S1 | (DE “Post-Traumatic Stress”) OR “combat disorders” OR “Post Traumatic Stress Disorder” OR “Post Traumatic Stress Disorders” OR “Posttraumatic Stress Disorder” OR “Posttraumatic Stress Disorders” OR “PTSD” OR “Post Traumatic Neuroses” OR “Posttraumatic Neuroses” OR (DE “Psychosis”) OR (DE “Reactive Psychosis”) OR “Psychotic Disorder” OR “Psychosis” OR “Psychoses” OR “Schizoaffective Disorder” OR “Schizoaffective Disorders” OR “Schizophreniform Disorders” OR “Schizophreniform Disorder” OR (DE “Brain Damage”) OR (DE “Periventricular Leukomalacia”) OR (DE “Traumatic Brain Injury”) OR (DE “Brain Concussion”) OR (DE “Head Injuries”) OR “traumatic brain” OR “brain trauma” OR TBI OR “intracranial injury” OR “intracranial injuries” OR “traumatic encephalopathy” OR “posttraumatic encephalopathy” OR “post traumatic encephalopathy” OR “cerebral trauma” OR (“blast—induced” AND brain) OR “multiple trauma” OR “multiple traumas” OR “multiple wound” OR “multiple wounds” OR “multiple injury” OR “multiple injuries” OR Polytrauma OR “Poly trauma” OR Polytraumas OR “Poly traumas” OR Polytraumatised OR “Poly traumatized” OR “Polytraumatic” OR “Poly traumatic” OR “serious mental illness” OR (((DE “Military Veterans”) OR (DE “Traumatic Neurosis”) OR (DE “Adjustment Disorders”) OR veterans OR veteran) AND ((DE “Cognitive Impairment”) OR (DE “Intellectual Development Disorder”) OR (DE “Cognitive Ability”) OR (DE “Brain Training”) OR (DE “Mathematical Ability”) OR (DE “Reading Ability”) OR (DE “Spatial Ability”) OR (DE “Verbal Ability”) OR “cognition disorder” OR “cognition disorders” OR “Cognitive Dysfunction” OR (DE “Cognitive Impairment”) OR “Cognitive impairment” OR “cognitively impaired” OR “Functional impairment” OR “functionally impaired” OR “Executive Dysfunction” OR “Cognitive Deficits”)) | 139,229
S2 | ((DE “Home Care”) OR “home nursing” OR “home-based” OR “Nonprofessional Home Care” OR “Non-Professional Home Care” OR “informal care” OR “informal caregiver” OR “informal caregivers” OR “informal carer” OR “informal carers” OR “informal caregiving” OR “informal caretaker” OR “informal caretakers” OR “informal social support” OR “family-inclusive”)) OR (((DE “Caregivers”) OR (DE “Caring Behaviors”) OR caregiver OR caregivers OR carer OR carers OR caregiving OR “care giving”) AND (“custodial” OR “domiciliary” OR “respite” OR “home” OR “Community Dwelling” OR (DE “Social Environments”) OR (DE “Social Support”) OR “Psychosocial Support”)) OR (((DE “Caregivers”) OR (DE “Caring Behaviors”) OR caregiver OR caregivers OR carer OR carers OR caregiving OR “care giving”) AND ((DE “Family”) OR family OR families OR relatives OR stepfamily OR stepfamilies OR kinship OR friend OR (DE “Marriage”) OR marriage OR married OR wedded OR (DE “Spouses”) OR spouse OR spouses OR spousal OR wife OR wives OR husband OR husbands OR girlfriend OR boyfriend OR “domestic partner” OR “domestic partners” OR “domestic partnership” OR “domestic partnerships” OR (DE “Interpersonal Relationships”) OR “interpersonal relations” OR “intimate partner” OR “intimate partners” OR “intimate partnership” OR “intimate partnerships” OR “intimate relationship” OR cohabitate OR cohabitant OR cohabitants OR parent OR parents OR parental OR stepparent OR stepparents OR mother OR mothers OR moms OR Father OR fathers OR dads OR stepfather OR stepfathers OR son OR sons OR stepson OR stepsons OR child OR children OR daughter OR daughters OR stepdaughter OR stepdaughters OR uncle OR uncles OR aunt OR aunts OR sibling OR siblings OR sister OR sisters OR stepsister OR stepsisters OR brother OR brothers OR stepbrother OR stepbrothers OR cousin OR cousins OR grandparent OR grandparents OR grandmother OR grandmothers OR grandfather OR grandfathers)) | 52,755
S3 | S1 AND S2 | 2,082
S4 | S3 Limiters - Language: English; Age Groups: Adulthood (18 yrs & older) | 1,248
S5 | TI (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomization” OR “randomised” OR “randomisation” OR “randomly” OR “trial” OR “groups” OR “comparative study” OR “nonrandom” OR “non-random” OR “nonrandomized” OR “non-randomized” OR “nonrandomised” OR “nonrandomised” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study)) OR “pre-post” OR “posttest” OR “post-test” OR “pretest” OR “pre-test” OR (“time series” AND “interrupt”) OR ((“time points”) AND (multiple OR one OR two OR three OR four OR five OR six OR seven OR eight OR nine OR ten OR month OR monthly OR day OR daily OR week OR weekly OR hour OR hourly)) OR (before AND after) OR (before AND during) OR “systematic review” OR “Umbrella Review” OR “meta-analysis” OR “meta-analyses” OR “meta-synthesis” OR “meta-syntheses”) OR AB (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomization” OR “randomised” OR “randomisation” OR “randomly” OR “trial” OR “groups” OR “comparative study” OR “nonrandom” OR “non-random” OR “nonrandomized” OR “non-randomized” OR “nonrandomised” OR “non-randomised” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study)) OR “pre-post” OR “posttest” OR “post-test” OR “pretest” OR “pre-test” OR (“time series” AND “interrupt”) OR ((“time points”) AND (multiple OR one OR two OR three OR four OR five OR six OR seven OR eight OR nine OR ten OR month OR monthly OR day OR daily OR week OR weekly OR hour OR hourly)) OR (before AND after) OR (before AND during) OR “systematic review” OR “Umbrella Review” OR “meta-analysis” OR “meta-analyses” OR “meta-synthesis” OR “meta-syntheses”) | 707,730
S6 | S5 NOT PT (Abstract OR Book OR Book Chapter OR Book Review OR Case Study OR Commentary OR Doctoral Dissertation OR Editorial OR Letter OR Masters Thesis OR Pamphlet OR Pamphlet Chapter OR Poetry) NOT TI (Editorial OR Letter OR “Case Report” OR Comment) | 668,325
S7 | S3 AND S6 | 349