# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 What is the incidence of severe hypoglycemia in adults with type 2 diabetes on one or more hypoglycemic agents?

Overall incidence of severe hypoglycemia was less than 1% in the majority of the 60 reviewed studies, particularly those of metformin (0–1.5%), GLP-1 analogs (< 1%), DPP-4 inhibitors (<1%), insulin detemir (<1%), glinides (0%) and TZDs (<1%). These rates are similar to the placebo or diet-only rates which were measured in three studies21, 29, 59, 136 with a pooled incidence of severe hypoglycemia of 0.6% (95% CI 0.3 to 1.2%) over a weighted mean follow-up time of 7 years. These results are consistent with other high quality systematic reviews of exenatide,62, 63 liragultide,63 sitagliptin,64 glinides71 and pioglitazone.70 These results are also consistent with a recent meta-analysis of a wide variety of OHAs that concluded that severe hypoglycemia did not “occur more often with any particular monotherapy or combination therapy” but that the sulfonylureas were the most likely to increase the risk.137 However, Bennett did not include insulins or intensive versus conventional control trials.

The treatment regimens with the highest risk were sulfonylureas, those targeting intensive control of HbA1c levels and insulin (in particular NPH, glargine, lispro, and glulisine). For the [underlined: sulfonylureas] the pooled incidence of severe hypoglycemia was 1.2% (95% CI 0.9 to 1.5%) over a weighted average follow-up time of 2.4 years. Due to limited data we were unable to determine incidence rates associated with individual sulfonylureas.

In the five trials that randomized participants to [underlined: intensive versus conventional glycemic control]3–5, 21, 29, 30 the pooled incidence of severe hypoglycemia was 7.6% in the intensive group and 3.1% in the conventional group (RR 2.4, 95% CI 1.8 to 3.1, N= 27,644) over a weighted average follow up of 5.2 years. This is consistent with four other high quality meta-analyses that included these RCTs and other studies and that reported a 2- to 2.5-fold increased risk of severe hypoglycemia in intensively treated patients, with 5 year incidence rates of 2–3% with conventional control and 5–7% with intensive control.8–11 A post-hoc analysis of the ACCORD data indicated that participants whose HbA1c did not drop to target levels promptly were at the highest risk. The authors concluded that clinicians should not continue to intensify glucose lowering regimens when initial efforts are unsuccessful.89

#### Insulin

There were only two trials of NPH monotherapy, one of which reported a 5 year incidence of 11.1%^35^ and one a 6 month incidence of 2.3%.39 These results are consistent with two meta-analyses, one which identified no cases of severe hypoglycemia in 14 RCTs with an average follow-up of 40 weeks.69 The second reported an incidence of severe hypoglycemia of 2.6% in six studies with 1532 subjects followed for 6 months to 1 year.66 Overall, it appears that the annual incidence of severe hypoglycemia in persons on NPH monotherapy is about 0–3%.

For NPH with OHAs we documented a pooled incidence of severe hypoglycemia of 5% (95% CI 4.1 to 6.1%, N=3150), over a weighted average followup time of 1.2 years. This is consistent with the results of a large trial in which an insulin-based strategy to lower HbA1c to less than 7% was associated with a 9.2% 5-year incidence rate58 and another systematic review which compared long-acting insulin analogues to NPH insulin with or without concomitant OHAs and reported a 6 month 2.7% incidence of severe hypoglycemia66 However, a review by Goudswaard,69 which investigated either insulin monotherapy or combinations of insulin plus OHAs, identified only one severe hypoglycemic episode in a patient on morning NPH plus a sulfonylurea. In this review, 12 unique studies reported rates of hypoglycemia, none of which were included in our review because either they enrolled fewer than 500 subjects, were not published in English or were less than 6 months in duration.

Insulin detemir, a long-acting insulin analogue, was associated with a low incidence (<1%) of severe hypoglycemia, consistent with another systematic review (also including only studies of at least 6 months duration) which reported an incidence of 1.2% (7/578) in two studies.66 However, a third review reported an incidence of severe hypoglycemia of 3.0% in four RCTs with a total of 1247 patients.65 Since this review included studies as short as 12 weeks in duration and hypoglycemic episodes are known to occur more frequently during initiation of therapy, this may explain the discrepancy between the reviews.

Insulin glargine was evaluated in eight studies. Results from three long term studies (pooled incidence 4.1%, 95% CI 1.9 to 8.4%, N=1223) and five short-term studies (pooled incidence 1.6%, 95% CI 0.8 to 3.2%, N=13,088) are consistent with the findings of two other recent meta-analyses in which risk of severe hypoglycemia with glargine was found to be 3.2%^65^ and 1.9%.66

Among the short (or fast) acting insulin analogues (lispro, aspart, glulisine), for [underlined: lispro], the pooled incidence of severe hypoglycemia was 3.6% (95% CI 2.3 to 5.4%, N=1198) over a weighted average follow-up time of 1.3 years. For [underlined: aspart], the pooled incidence of severe hypoglycemia was 0.2% (95% CI 0.2% to 0.2%, N=54,425) over a weighted average follow-up time of 6 months; this analysis however was dominated by a very large observational study conducted in physician offices in 11 countries and funded by a pharmaceutical company.22 If the analysis is repeated without this study the incidence is 1.5% (95% CI 0.9 to 2.5%) over a weighted mean average follow-up of years 1.2 years. For [underlined: glulisine] (combined with NPH insulin) the incidence of severe hypoglycemia was 1.0% (95% CI 0.5 % to 2.1%, N=883) over a weighted average follow-up time of 6 months.

In a meta-analysis comparing these insulins with either non-insulin agents, premixed human insulin, or long-acting insulin analogues in adults with type 2 diabetes, Qayyum found that there was no significant difference in risk of serious hypoglycemia.138 A Canadian health technology report came to a similar conclusion, stating that there was no significant difference in severe hypoglycemia between treatment with human insulin or the insulin analogues.68 A Cochrane review reported a median incidence of 0.3 severe hypoglycemic episodes (range 0 to 30.3) per 100 patient-years.67 The authors attributed the wide range to the inclusion of a single study with a very short duration of follow-up.

#### Key Question #1 Extension

Of the additional 16 studies reviewed to gain a broader population-based perspective on incidence of severe hypoglycemia, 13 were survey studies reporting patient-recalled rates. Eleven of these asked patients to report on events in the past 6 months (N=6) to 1 year (N=5). In these 11 studies, patient reported incidences of HA varied widely from 1% to 17%. Although hypoglycemic agents are among the most commonly implicated drugs in adverse event reports and ER visits (see Key Question #3 discussion), these data do not cast any light on incidence. In the two studies least likely to be affected by recall bias, one which recorded events within the past 2 weeks86 and the prospective study in Scotland,72 the incidence of symptomatic hypoglycemia was 14% over 2 weeks in the former and 3% over one month in the latter. The discrepancy is likely due to Donnelly et al.’s more restrictive definition of hypoglycemia (HA as opposed to symptomatic only).

#### VA Specific Data

Among the studies included herein, four reported specifically on VA patients.5, 30, 74, 75 In addition we identified two VA publications which did not meet our inclusion criteria. One was an unpublished abstract examining VA administrative data reporting that 22% of 1.4 million veterans with diabetes had a hypoglycemic associated medical encounter over 5 years. It is unclear from the abstract how the diagnoses were confirmed and what the severity of the episodes were. The second, published after our search was concluded, evaluated the incidence of hypoglycemia as determined by administrative records in 497,900 veterans aged 65 or older.139 That study found that 7.5% of subjects had one or more inpatient or outpatient visits in which a code for hypoglycemia was recorded over 24 months.

Although suggestive of increased rates of hypoglycemia among veterans with diabetes, it is difficult to derive definitive conclusions from these VA studies since there is substantial heterogeneity with respect to definitions of hypoglycemia, study design, subject inclusion criteria, treatment regimens and lengths of follow-up.

#### Limitations of Available Studies

Much of the evidence comes from reports of RCTs funded by pharmaceutical companies which enroll highly selected populations and generally do not include those at highest risk for hypoglycemia. Second, the definitions of severe hypoglycemia varied among studies and there is likely substantial ascertainment bias, especially in the RCTs designed primarily to measure the benefits of specific drug regimens. Finally, there are few studies that investigated regular insulin, generally thought to be associated with high rates of hypoglycemia.

#### Conclusion for Key Question #1

The incidence of severe hypoglycemia is about 0–3% per year for adults with type 2 diabetes on hypoglycemic medications. Risk is highest for insulins, sulfonylureas and regimens targeting intensive control of HbA1c levels. Risk is lowest for metformin, GLP-1 analogs, DPP-4 inhibitors, glinides and TZDs. Since most of these data are derived from pharmaceutical company funded RCTS which enrolled highly selected populations, the generalizability of the results is unclear. Indeed, one small population based prospective study suggests that the incidence may be as high as 3% per month in community based subjects treated with insulin.72 Furthermore, several studies performed in VA suggest that incidence of hypoglycemia may be higher in this population. Larger population-based prospective studies of people on a variety of hypoglycemic agents that employ accurate methods for ascertaining incidence of severe hypoglycemia should be performed.

Even with this relatively low incidence of severe hypoglycemia, given the high prevalence of diabetes in the general population1 and in the VA, there are likely tens of thousands of people in the US experiencing severe hypoglycemia every year. These episodes tend to be frightening, and may lead to more severe consequences (see Key Question #3 below) and to reluctance to pursue optimal blood sugar control.140 They may also be associated with significant costs to the health care system.141

### Key Question #2 What are the risk factors for severe hypoglycemia in adults with type 2 diabetes on one or more hypoglycemic agents (e.g., demographics, co-morbidities, diabetes treatment regimen, other medication use, goal and achieved HbA1c)?

We identified 14 articles from 12 studies that reported multivariate adjusted risk factor analyses for severe hypoglycemia in adults with type 2 diabetes on hypoglycemic mediations. Since these varied considerably with respect to risk factors evaluated (and their definitions), populations studied, and lengths of follow-up, the data were considered unsuitable for pooling. Transient causes (e.g., missed meal, excess exercise, alcohol use, acute infection) were not included.142

The factors evaluated in the 12 multivariate analyses are discussed below. In addition, genetic markers, marital status, smoking, alcohol consumption, polypharmacy, recent discharge from the hospital, congestive heart failure and use of ACE inhibitors were all identified in at least one of these 12 studies as independent risk factors for severe hypoglycemia. However, the findings for these risk factors were generally sparse, often conflicting, and ultimately inconclusive.

#### Independent Risk Factors

Factors most consistently and independently associated with risk include: intensive glycemic control (discussed above under Key Question #1), history of hypoglycemia, renal insufficiency, history of microvascular complications, longer diabetes duration, lower education level, African American race and history of dementia. History of hypoglycemia unawareness, gender, age and BMI are not consistently associated with risk, although higher age and lower BMI were associated with higher risk in the two largest studies.

[underlined: Previous hypoglycemia] which was evaluated in four studies, appears to be one of the strongest risk factors for a severe hypoglycemic event (three to nine-fold increased risk) and is often listed as a well known risk factor in reviews of this topic.142, 143 Repeated episodes of hypoglycemia are thought to lead to autonomic insufficiency, a state in which patients become unaware of the common symptoms of low blood sugar, such as palpitations and lightheadedness. This unawareness may then lead to failure to take corrective action resulting in more episodes, thus establishing a vicious cycle.144

[underlined: Renal insufficiency] was evaluated in seven studies, five of which found it to be a significant independent risk factor for severe hypoglycemia. The two studies that did not find a significant association were either very small102 or recorded very few episodes of severe hypoglycemia.100 Renal insufficiency is a well known risk factor for hypoglycemia; the reduced clearance of insulin in the diseased kidney causes relative hyperinsulinemia which can lead to hypoglycemia.141, 143 Hypoglycemia in renal insufficiency may also be due to reduced clearance of antidiabetic agents145 and a decrease in renal gluconeogenesis.146

The relationship between renal insufficiency, hypoglycemic agents and incidence of severe hypoglycemia, however, is complicated. A nested case control study of 558 people with diabetes over the age of 65 on insulin, metformin or glyburide investigated whether renal function was an effect modifier for the association between glyburide or insulin use and hypoglycemia.147 Since the study did not distinguish between severe and other forms of hypoglycemia, it was not included in our review. Results indicated that while renal function did not significantly modify risk of glyburide associated hypoglycemia, risk of insulin-associated hypoglycemia was, unexpectedly, attenuated by renal dysfunction.

The relationship between [underlined: non-renal microvascular disease] and severe hypoglycemia was evaluated in five studies. In three of the five studies, there were significant positive associations between peripheral neuropathy (or its manifestation, leg ulcerations) and risk of severe hypoglycemia with risk ratios in the 1.2 to 2.4 range; the largest of these three studies, ACCORD,3 found the lowest risk. In a fourth study, “history of microvascular disease,” which also included renal disease, conferred a twofold increased risk of severe hypoglycemia (HR 2.1, 95% CI 1.5 to 3).4 The pathophysiologic mechanism underlying this association is unclear. Although microvascular complications are an indicator of longstanding diabetes, duration of diabetes was often controlled for in these analyses.

[underlined: Diabetes duration] was associated with a modestly increased risk for severe hypoglycemia in studies (with odds ratios of less than 2) and is thought to be due to the compromised ability of people with advanced type 2 diabetes to mount an appropriate counter-regulatory hormonal (insulin, epinephrine, and glucagon) response to low blood sugar.141, 143

Demographic variables such as [underlined: African American race] and [underlined: lower education level] were both independently associated with a modestly increased risk of severe hypoglycemia. In the studies that evaluated race, blacks were significantly more likely than whites to experience severe hypoglycemia, with relative risks of 1.4 to 2.0. This association was independent of other known risk factors, such as education, that may track with race.89

Four of five studies that evaluated education, reported significant positive associations between lower education level and risk of severe hypoglycemia. One of these found the risk associated with low literacy rates, a more specific construct than education level, was associated with close to a four-fold increased risk. However this study was a case-control study that included fewer than 300 subjects leading to wide confidence intervals around the odds ratio.104 It has been speculated that persons with low levels of education and literacy may not fully understand how to take their hypoglycemic medications or how to treat incipient hypoglycemia.

[underlined: Dementia] was found to be an independent risk factor for severe hypoglycemia in two of three studies. As is expected based on sample size, the much larger of these two studies (N=11,140)4 found a modestly increased risk with a very tight confidence interval, whereas the smaller study (N=302),92 found a larger risk with a very wide confidence interval. The only study that did not find an association was very small.103 In addition, an article from ACCORD that was not included in our review because it was published in 2012, also found a significant association between poor cognitive function and risk of HMA.148 Dementia may increase the likelihood of errors in self-medication and of inability to recognize and treat incipient hypoglycemia.141

#### Risk Factors NOT Found to be Independently Associated with Risk

[underlined: Gender, age and low BMI] were not consistently associated with risk, although age and low BMI were significantly predictive of risk of severe hypoglycemia in the two largest trials.3, 4 It has been suggested that older people may be at increased risk due to diminished counter-regulatory and autonomic system responses to low blood sugar149 and may be more likely to suffer from hypoglycemia unawareness.150 Low BMI may contribute to hypoglycemia because of poor nutrition, decreased glucose absorption, or erratic meal plans. In contrast to age and BMI, the results for gender were conflicting in the two large trials: ACCORD found that women were at modestly increased risk compared with men whereas ADVANCE found no significant difference between men and women.

[underlined: Impaired hypoglycemic awareness] was only evaluated in one of our included studies.84 Although this study found a significant increased risk, it employed a weak study design (cross sectional) and had relatively few subjects (N=401).

#### Other Literature

We did not identify any other systematic reviews that evaluated risk factors for severe hypoglycemia in people with type 2 diabetes. One literature survey included six prospective and five retrospective studies that enrolled at least 50 participants all on insulin followed for at least 6 months.151 The risk factors identified included impaired hypoglycemia awareness, advanced age, longer duration of diabetes and of insulin therapy. HbA1c at baseline and dose of insulin were not found to increase risk. However this study included only insulin treated patients, did not limit its review to studies using multivariate analysis, and antedated publication of the three large trials of intensive versus conventional control.

An unpublished abstract examining VA administrative data reported the following risk factors for an inpatient or outpatient diagnosis of hypoglycemia: prior hypoglycemia, history of ketoacidosis or hyperosmolar coma, high HbA1c levels, recent initiation of a new medication, recent hospitalization, use of secretagogues, insulin, fluoroquinolones or tricyclic antidepressants, higher age, low SES (which often correlates with education level) and unmarried status. It is unclear from the abstract how the diagnoses were confirmed and what the severity of the episodes were. In addition, a paper published after our literature search was concluded indicated that dementia and cognitive impairment were independent risk factors for hypoglycemia among older veterans,139 consistent with our findings.

#### Limitations of Available Studies

The data are relatively sparse and almost certainly reflect publication bias (negative analyses are less likely to be published). In addition we were unable to pool results across studies due to the heterogeneity of the study designs, analytical methods, and risk factors assessed. Finally, only two studies used negative binomial or zero inflated poisson16, 84, 93 methodology which may be less likely than standard regression techniques to yield spurious associations in situations in which there are frequent zero counts.152

#### Conclusion for Key Question #2

Independent risk factors for severe hypoglycemia in persons with type 2 diabetes on hypoglycemic medication include: intensive diabetes control, history of hypoglycemia, renal insufficiency, history of microvascular complications, longer diabetes duration, lower education level, African American race and history of dementia. Gender, age and BMI are not consistently associated with risk, although in the two largest studies, higher age and lower BMI were significantly associated with higher risk.

### Key Question #3 What is the effect of severe hypoglycemia on other outcomes in adults with type 2 diabetes on one or more hypoglycemic agents (e.g., quality of life, mortality, morbidity, utilization)?

Severe hypoglycemia causes brain fuel deprivation that, if uncorrected, can lead to neurological compromise and death.143 There is uncertainty about a possible link between hypoglycemia and mortality, cardiovascular events, and other adverse health outcomes.153–155 Based on studies included in this review, we found no evidence of increased short-term mortality and limited evidence that a history of severe hypoglycemia increases long-term mortality. Few cardiovascular events were reported; coma and seizures were present in 5% to 71% of patients with severe hypoglycemia.

A recent study of over 850,000 patients found greater odds of an acute cardiovascular event during a one year period in type 2 diabetic patients who also experienced a hypoglycemic event (not necessarily severe) during that period (OR 1.79, 95% CI 1.69 to 1.89). The analysis included adjustment for baseline cardiovascular risk factors, comorbidities, and prior cardiovascular events (all of which were significantly more prevalent in the hypoglycemia group).156 In a study of adverse events reported to the Food and Drug Administration from 1998 through 2005, there were 9597 reports of insulin-associated disability or other serious but non-fatal outcome.157 However, in a study of patients hospitalized with acute MI, not all of whom had diabetes, spontaneous hypoglycemia in patients not treated with insulin was associated with increased risk for mortality; among patients treated with insulin, hypoglycemia was not associated with increased risk for mortality. This would suggest that hypoglycemia, itself, does not cause adverse events but is, instead, a marker of severe illness.158 People who are likely to experience hypoglycemia may also be likely to experience other serious health outcomes due to other risk factors.155

It is well known that cognitive and psychomotor function decline during a hypoglycemic episode.159, 160 Therefore, it is theorized that driving performance would be affected. However, whether severe hypoglycemia is associated with an increase in motor vehicle crashes is uncertain. Data from early studies are of questionable value as a result of improvements in methods for self-monitoring of blood glucose and changes in available medications.161 A more recent study found a nearly four-fold increased risk of a history of severe hypoglycemia in those who experienced a motor vehicle crash.129

Much of the information about driving performance is from laboratory studies where hypoglycemia is induced and driving simulators are used. In a recent study of 20 type 2 diabetic individuals with normal hypoglycemic awareness (mean age 52 years, all of whom had a driver’s license for at least 2 years), 11 of the 20 felt hypoglycemic. Of those 11, five (45%) said they would measure their blood glucose and six (55%) said they would not drive. Nine of the 20 “maybe” felt hypoglycemic. Of those nine, three (33%) said they would drive, two (22%) said they would “maybe” drive, two (22%) said they would measure their glucose and two (22%) said they would not drive.130 It is unknown how results from studies of this type translate to actual driving performance or behavior.

Long-term effects of hypoglycemia, especially repeated episodes of severe hypoglycemia, on cognitive performance are not fully understood.159, 160 Results, to date, in patients with type 2 diabetes have been mixed.92, 94 The DCCT/EDIC trial in patients with type 1 diabetes found neither frequency of severe hypoglycemia nor initial treatment group assignment (intensive versus conventional therapy) were associated with cognitive decline over 18 years based on a battery of 17 tests representing eight cognitive domains.162 The ACCORD-MIND study reported no differences in cognitive outcomes between intensive treatment and standard treatment groups at 40 months. The authors did not relate their findings to the presence or absence of severe hypoglycemic episodes.163

Data from the Edinburgh Type 2 Diabetes Study were recently published.164 Participants, all age 60 to 75 years, were asked about severe hypoglycemic events. A history of severe hypoglycemia (one or more episodes) was associated with lower cognitive ability as reflected by the Letter-Number Sequencing test (p=0.03), the Trail-Making Test (p=0.004), and a composite score based on seven cognitive tests (p=0.04). Results were adjusted for prior cognitive ability, demographic characteristics and comorbid conditions. Similar findings were noted for the analysis based on severe hypoglycemia in the year preceding cognitive testing.

Potential reasons for differences across studies have been suggested in the literature. Many studies of cognitive function completed to date may not have sufficient follow-up time to adequately address long-term effects.159 Differences observed between studies may be due to differential effects of hypoglycemia on the brain in younger versus older people.160 Increased risk of dementia associated with type 2 diabetes may be due to other factors (e.g., depression, vascular disease, comorbid conditions and associated medications and genetic predisposition).165 Alternatively, an observed association between hypoglycemia and cognitive decline may be due to the fact that patients with cognitive decline may be less able to manage their diabetes and therefore may experience more hypoglycemic events.159

Hypoglycemia, particularly severe hypoglycemia, results in utilization of health care resources. In studies included in this review, we observed that between 0% and 31% of episodes of severe hypoglycemia were seen in an emergency department and between 0% and 33% of episodes resulted in hospital admission. Increased physician visits were also reported. A recent systematic review recommended increased hospitalization and primary care visits for post-hypoglycemic patients.166 Citing the potential for repeat hypoglycemia, as reported in studies of post-hypoglycemic type 2 diabetes patients taking oral hypoglycemic agents and first treated for a hypoglycemic episode in a prehospital environment, the authors recommended conservative management (i.e., transportation of all patients to a hospital for observation and treatment). They also encouraged the development of evidence-based interventions to increase primary or specialty care visits by post-hypoglycemic patients.

In a study examining nationally representative data, Budnitz et al.167 estimated that insulin, metformin, glyburide and glipizide were implicated in 13%, 2.3%, 2.2%, and 1.5% of all emergency department visits in the United States in persons age 65 and older. These four were among the top 10 most commonly implicated medications.167 In a more recent study, this group estimated that insulin and oral hypoglycemic agents accounted for 25% of all adverse drug event-associated emergency hospitalizations in the United States in 2007–2009.^168^ These studies did not link the emergency department visits or hospitalizations to episodes of severe hypoglycemia.

#### Limitations of Available Studies

Few studies that address outcomes of severe hypoglycemic episodes include appropriate control groups. In addition, many outcomes of interest were not widely reported.

#### Conclusion for Key Question #3

There is good data that severe hypoglycemia is associated with an increased risk of the following outcomes: all-cause mortality (particularly long-term), neurological events (other than non-fatal stroke), hospital and emergency department utilization, and decreased quality of life. There is limited data about many other outcomes of interest including non-fatal MI, non-fatal stroke, cognitive decline, motor vehicle accidents, falls and traumatic injuries, work productivity, and other medical service utilization. In the absence of appropriate control groups it is unclear if many of these outcomes are hypoglycemia-related or simply reflect the age and co-morbidity burden of the population.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Key Question #1: Larger population-based prospective studies of people on a variety of hypoglycemic agents that employ accurate methods for ascertaining incidence of severe hypoglycemia should be performed. Studies need to control for or stratify outcomes by important patient, disease and comorbidity factors including: age, gender, race/ethnicity, socio-economic and marital status, disease duration and severity (e.g., HbA1c level, presence or absence of diabetic complications).

Key Question #2: Future research should include studies in VA patients and include the more intriguing possible risk factors including smoking or recent hospital discharge. In addition, future research may lead to the development of a risk factor index if outcomes are significant enough to warrant risk stratification.

Key Question #3: Future studies of outcomes associated with severe hypoglycemia should be prospective, use a uniform and generally accepted definition of severe hypoglycemia, and include, as controls, people with medication-treated diabetes who have not experienced severe hypoglycemia. Also, studies should clearly distinguish between short-term or episode-related versus long-term consequences.

Specific future research needs include:

a. To clarify the association between hypoglycemia and cardiovascular events, research is needed to better understand the effects of hypoglycemia on blood constituents and the vascular system and larger clinical trials are needed to determine whether hypoglycemia is a cause of cardiovascular events.153, 154 Better understanding of the role of hypoglycemia in patients already at risk for developing vascular disease is also needed.153
b. There is a need for a large-scale, prospective study of accident rates in patients with diabetes compared to appropriate control groups.161 Better understanding is needed of which driving skills are most likely to be affected by hypoglycemia, at what level of blood glucose driving impairments become observable, and whether results obtained in a laboratory translate to road conditions.134
c. Additional research is needed to assess the overall effect of hypoglycemia on patients with type 2 diabetes including quality of life outcomes (both work and recreational). To date, much of the research has focused on type 1 diabetes and the emphasis has been on hypoglycemia as a safety issue.169
d. To assess the effect of hypoglycemia on cognitive function, large-scale epidemiological studies with detailed phenotyping of clinical variables and randomized trials of interventions (therapeutic and preventive) that include cognitive testing and brain structure/function assessments are needed.165, 170