# RESULTS

## LITERATURE FLOW

We reviewed 2353 titles and abstracts from the electronic search. After applying inclusion/exclusion criteria at the abstract level, 1914 references were excluded. We retrieved 439 full-text articles for further review and another 320 references were excluded. We identified 8 references by hand searching reference lists of relevant publications resulting in a total of 127 references for inclusion in the current review. We grouped the studies by key question. We re-reviewed excluded studies to identify studies that might address a more population-based perspective on hypoglycemia incidence (Key Question #1-Extension). Sixteen articles were included in this extended view of incidence. Figure 2 details the exclusion criteria and the number of references related to each of the key questions.

Figure 2 Literature Flow Diagram

^*^ A number of articles provided data for more than one KQ. Therefore, the total number of included articles does not equal the sum of the articles for each key question.

## KEY QUESTION #1 What is the incidence of severe hypoglycemia in adults with type 2 diabetes on one or more hypoglycemic agents?

We identified 72 articles on 60 studies that provided data to address Key Question #1. We also identified 21 systematic reviews that were not funded by industry and provided severe hypoglycemia data. Four of the reviews included only the “intensive versus conventional” studies while 17 reviewed specific drugs or drug combinations.

### Overview of Included Studies (Appendix E, Table 1)

The 60 studies included 46 RCTs (N>75,000), eight prospective observational studies,15–22 and six retrospective studies.23–28 Five of the RCTs randomized participants to an intensive versus a conventional treatment strategy, and not to specific drug regimens.3–5, 21, 29, 30 Thirty were multinational, eighteen were conducted in the US and/or Canada, six in the United Kingdom, five elsewhere, and in one it was unclear.31 Forty-seven were funded exclusively by pharmaceutical companies, ten by government research institutes with or without supplementary pharmaceutical support, and funding for three studies was not reported.28, 32, 33 All studies enrolled both men and women except one VA study which enrolled only men.30 Among the RCTs, most enrolled a broad age range of patients from age 18 to no upper age limit; only three had a lower age limit of 40.^3, 5, 30^ As shown in Appendix E, Table 1 there was a wide spectrum of hypoglycemic treatment regimens and of other inclusion criteria.

#### Definition of Severe Hypoglycemia

All 60 studies met our pre-specified minimal definition of severe hypoglycemia: an episode with typical symptoms (e.g., sweating, dizziness, tremor, visual disturbance) that resolves after treatment (oral carbohydrate, intramuscular glucagon, or intravenous glucose) administered by another person. Adopting the language used in ACCORD,3 we refer to this type of episode as HA—Hypoglycemia needing any Assistance. Thirty-seven studies used this definition exclusively. Six studies required that the episode be treated by medical personnel to qualify as “severe”—referred to as HMA (Hypoglycemia requiring Medical Assistance); ten studies used other definitions (see Appendix E, Table 1); and seven studies categorized events by more than one definition.

#### Study Quality

As shown in Appendix D, Table 1, only 26% (n=12) of the 46 unique randomized studies were rated as a good quality study or having a low risk of bias based on adequate allocation concealment, blinding, analysis by intent-to-treat, and adequate study withdrawal reporting. The remaining studies were assessed as fair quality with an unclear risk of bias. Adequate methods used to conceal allocation was reported in 41% (n=19) of the studies, and any blinding (participants, personnel, and/or outcome assessors) was reported in 63% (n=29) of studies. Most studies analyzed data based on randomized subjects who had taken at least one dose of study medication (modified intent-to-treat). Reasons for dropouts/attrition were generally reported. Nearly all studies reported funding from pharmaceutical industries.

Among the 14 unique non-randomized studies for Key Question #1, eight were prospective cohort studies, five were retrospective cohort studies and one was a case series (Appendix D, Table 2). Although our intent was to exclude case series, this study was originally misclassified and was retained in our analysis. Most studies used a study sample that pertained to the population of interest, included inclusion/exclusion criteria, and used appropriate sampling methods. Outcomes reporting and measurement assessment were considered appropriate in nearly all studies. Methods for minimizing confounding were reported in seven of the studies.

### Results

We tabulated frequency of severe hypoglycemia by treatment regimen (Appendix E, Table 3). Overall incidence of severe hypoglycemia was low in most studies, particularly studies of metformin monotherapy (<1%), GLP-1 analogs (< 1%), DPP-4 inhibitors (<1%), glinides (0%), detemir (<1%) and TZDs (<1%). In the single study evaluating pramlintide, the incidence of severe hypoglycemia was less than 2%, the same as the placebo incidence.34 We pooled incidence data for specific treatment regimens as detailed below.

#### Long-acting Insulins

There were eight studies of [underlined: insulin glargine],35–42 three long term (pooled incidence 4.1%, 95% CI 1.9 to 8.4%, N=1223) and five short-term (pooled incidence 1.6%, 95% CI 0.8 to 3.2%, N=13,088) (Appendix F, Figure 1). There were three [underlined: insulin detemir] studies18, 40, 43 (Appendix F, Figure 2), two long-term (incidence 1.4%, 95% CI 0.7 to 2.9%, N=525) and one moderate term (incidence 0.4%, 95% CI 0.1 to 0.9%, N=1129). [underlined: NPH insulin monotherapy] was studied in two trials35, 39 (Appendix F, Figure 3), with a pooled incidence of 9.3% (95% CI 7.3 to 11.8%, N=763) over a weighted average follow-up time of 3.5 years. Six studies with eight treatment arms evaluated [underlined: NPH insulin in combination with other glucose lowering medications]35, 39, 41, 44–46 (Appendix F, Figure 4). Five of the six studies were short-term and one was long-term. Pooled incidence was 5.0% (95% CI 4.1 to 6.1%, N=3150) over a weighted average follow-up time of 1.2 years. We also pooled relative risks for [underlined: NPH versus glargine] (Appendix F, Figure 5). For this comparison there were three trials,35, 39, 41 one long term and two short-term. There was no difference in risk over a weighted average follow-up time of 2.5 years, (RR 1.37, 95% CI 0.66 to 2.81, N=2291)

#### Fast-acting Insulin Analogues

In the two [underlined: lispro] studies,36, 47 the pooled incidence of severe hypoglycemia was 3.6% (95% CI 2.3 to 5.4%, N=1198, Appendix F, Figure 6) over a weighted average follow-up time of 1.3 years. In the four studies of [underlined: aspart],15, 22, 43, 48 the pooled incidence of severe hypoglycemia was 0.2% (95% CI 0.2% to 0.2%, N=54,225, Appendix F, Figure 7) over a weighted average follow-up time of 0.5 years. In the 2 studies of [underlined: glulisine] (combined with NPH insulin),45, 46 the incidence of severe hypoglycemia was 1.0% (95% CI 0.5 % to 2.1%, N=883, Appendix F, Figure 8) over a weighted average follow-up time of 0.5 years.

In the 13 [underlined: sulfonylurea studies] (Appendix F, Figure 9), the pooled incidence of severe hypoglycemia was 1.2% (95% CI 0.9 to 1.5%, N=9081) over a weighted average follow-up time of 2.3 years.17, 18, 21, 32, 49–57

#### Insulin Provision versus Insulin Sensitization

One multinational factorial trial enrolled 2307 patients with type 2 diabetes and coronary heart disease and randomized them to either a percutaneous or surgical revascularization procedure and to either an insulin sensitization (metformin and TZDs most commonly used) or an insulin provision strategy (insulin and sulfonylureas most commonly used). The target HbA1c in both groups was less than 7%. The average length of follow-up was 5.3 years. The incidence of severe hypoglycemia was 5.9% in the insulin sensitization group and 9.2% in the insulin provision group58 (Appendix F, Figure 10).

#### Placebo

Two short-term (24 weeks) studies had a placebo only arm59, 60 and one long-term (10 years) study had a diet-only arm21, 29 with a total of 1312 subjects followed for a weighted average time of 7 years. The incidence of severe hypoglycemia was 0.6% (95% CI 0.3 to 1.2%). The two studies with placebo arms had rates of 0%.

#### Trials of Intensive versus Conventional Glycemic Control

Five trials randomized participants to intensive glycemic control versus conventional control3–5, 21, 29, 30 (Table 1, below). Length of follow-up ranged from 2.3 to 10 years, with a weighted average follow-up time of 5.2 years. The pooled incidence of severe hypoglycemia in these 5 trials was 7.6% in the intensive group and 3.1% in the conventional group (RR 2.4, 95% CI 1.8 to 3.1, N= 27,644, Appendix F, Figure 11).

Table 1 Incidence of Severe Hypoglycemia – Trials of Intensive vs. Conventional Glycemic Control

Study | Standard | Intensive | Average Follow-up (Years) | Definition | Glycemic Targets (conventional/intense)
ACCORD3 | 261/5123 (5.1%) | 830/5128 (16.2%) | 3.5 | HA | HbA1c 7.0 – 7.9/HbA1c < 6.0
ADVANCE4 | 81/5569 (1.5%) | 150/5571 (2.7%) | 5.0 | HA | Local standards/HbA1c ≤ 6.5
VA-DT5 | 28/899 (3.1%) | 76/892 (8.5%) | 5.6 | ** | HbA1c < 9/HbA1c < 6
VA-CSDM30 | 2/78 (2.6%) | 5/75 (6.6%) | 2.3 | HA | HbA1c < 13/HbA1c 4.0 – 6.1
UKPDS^#,21, 29^ | 8/1138 (0.7%) | 33/3071 (1.1%) | 10.0 | HA | FPG 6.1 – 15.0 mmol/l/FPG < 6.0 mmol/l

** life threatening or resulted in death, hospitalization, disability or incapacity

# data for the 2 UKPDS studies are combined as per Hemmingsen 2011^9^

HA—episode of hypoglycemia requiring assistance of another person

The largest of these trials was ACCORD3 which enrolled over 10,000 patients in the US and Canada and randomized them to receive intensive (target HbA1c <6%) or conventional (target HbA1c 7–7.9%) treatment. This trial was stopped early due to an increase in all-cause mortality in the intensively treated group. Although this group had a higher incidence of serious hypoglycemia requiring medical assistance (which might have explained the increased mortality), subsequent analyses did not confirm an association between hypoglycemia and increased mortality.61 The other four trials did not find increased all-cause mortality inthe intensively treated arms. This discrepancy may be explained by the fact that ACCORD3 was the largest of these trials and enrolled a higher risk population. For example, in ADVANCE,4 the next largest trial, fewer than 2% of subjects were on insulin at baseline compared to 35% of subjects in ACCORD. Similarly, average duration of diabetes and baseline level of HbA1c were higher in ACCORD than ADVANCE.

#### Other Meta-Analyses

We identified four high quality meta-analyses comparing intensive versus conventional control strategies.8–11 These reviews reported a 2- to 2.5-fold increased risk of severe hypoglycemia in intensively treated patients, with 5 year incidence rates of 2–3% with conventional control and 5–7% with intensive control. In addition, several high quality reviews have pooled data on specific diabetes treatments including exenatide,62, 63 sitagliptin,64 long-acting insulin analogs,65, 66 fast acting insulin analogs,67, 68 liragultide,63 insulin with or without oral hypoglycemic agents (OHAs),69 insulin with pioglitzone70 and glinides.71 As shown in Table 2, the frequency of severe hypoglycemia was less than1% in all these reviews.

Table 2 Frequency of Severe Hypoglycemia in Prior Reviews

Treatment | Reference | # of Studies^*^ | Frequency of Severe Hypoglycemia
Exenatide | Waugh62 | 7 | Rare episodes, mostly when combined with sulfonylureas
Exenatide | Shyangdan63 | 3 | 1 episode
Sitagliptin | Richter64 | 11 | 0 episodes
Glargine, Detemir (long acting insulin analogs) | Swinnen65 | 4 | No difference between determir and glargine
Glargine, Detemir (long acting insulin analogs) | Horvath66 | 4 | No difference between analogs and NPH
Lispro, Glulisine, Aspart (fast acting insulin analogs) | Siebenhofer67 | 14 | Incidence ranged from 0 to 30.3 (median 0.3) episodes per 100 pt-yrs compared to 0–50.4 (median 1.4) per 100 pt-yrs for people on regular insulin
Lispro, Glulisine, Aspart (fast acting insulin analogs) | Tran68 | 2 | No difference between Lispro 2/811 (0.1%) and Human Insulin 5/811 (0.6%)
Liragultide | Shyangdan63 | 3 (1.2 mg) 4 (1.8 mg) | [underlined: 1.2 mg dose]: 0 episodes; [underlined: 1.8 mg dose]: 6 episodes
Insulin with or without OHA | Goudsward69 | 14 | 1 episode
Insulin with Pioglitazone | Clar70 | 6 | “severe hypoglycemia rarely seen”
Glinides | Black71 | 5 | 4 studies had 0 episodes; 1 study (repaglinide) had 3 episodes (1%)

* reporting severe hypoglycemia

#### Extension of Key Question #1

In order to gain a more population-based perspective on hypoglycemia incidence, we re-reviewed all the abstracts identified through the initial search strategy (through November 2011) to find articles that might contain data from more representative groups that had not met the initial inclusion criteria (see Methods). From this search we identified 16 additional studies.

##### Overview of Included Studies

The 16 studies included 13 cross-sectional patient surveys, retrospective analyses of administrative data, and 1 prospective cohort study.72 Six of the studies were from the US, nine from Europe, and one from Asia.73 Ten were funded in whole or in part by industry, two by the VA,74, 75 three by foundations or other government agencies,76–78 and funding was not reported for one study.79 For more details on these studies see Appendix E, Table 2.

##### Patient Surveys (n=13)

Six reported events from the previous 6 months,73, 74, 78, 80–83 five from the previous year,76–79, 84 one from the previous 5 years85 and one from the previous 2 weeks.86 Seven studies included patients on any OHA, three on insulin only, two on a SU with or without metformin, and one on any combination of medications.79 Eleven studies categorized hypoglycemic events as requiring assistance from another person (six further categorized events as requiring medical (HMA) or non-medical assistance (HA)) and two had other definitions.80, 86 Sample sizes ranged from 215 to 5965.

All the survey studies which had 6 months of follow-up and reported severe hypoglycemia included patients on OHA only.73, 74, 82, 83, 87 In these five studies rates of HA were 1%, 2%, 4%, 9%, and 13% and of HMA were 2%,83 1%,82 4%,87 and 3%.73 In the three of the four studies with 1 year of follow-up,76, 77, 84 all of which included patients on insulin only, rates of HA were 12, 15 and 17 % and of HMA 2% (Honkasalo et al.77 only study to report). The four remaining survey studies included one in which 14% of 2074 patients on OHA only reported one or more symptomatic episodes (not necessarily severe) in past 2 weeks;86 one in which 27% of 1709 patients on OHA reported HA and 5% reported HMA over past 5 years;85 one in which symptomatic hypoglycemia (not necessarily severe) occurred in the previous 6 months in 20% of 203 patients;80 and one in which 27% of 635 people on insulin and 6% of 2689 people on OHA only reported HA in one year.79

##### Results from Other Studies (n=3)

- In a community based study in Scotland, a random sample of 173 adults with type 2 diabetes prospectively recorded hypoglycemic episodes over 1 month. Five (3%) experienced one or more severe episodes (required the assistance of another person).72
- In a US study using claims data from a privately insured population of adults age less than 65 with type 2 diabetes on either glargine (N=400) or NPH (N=400), 0.75% in each group had one or more hypoglycemia related outpatient claims during 1 year.88
- In a retrospective cohort analysis of 243,222 VA patients, diabetic patients with chronic kidney disease (CKD) had an average of 2.99 hypoglycemic events (glucose < 50) per 100 patient-months compared to 1.45 events in those without chronic kidney disease.75

### Summary of Key Question #1

Overall incidence of severe hypoglycemia was less than 1% in the majority of the 60 reviewed studies, particularly those of metformin monotherapy (<1%), GLP-1 analogs (<1%), DPP-4 inhibitors (<1%), insulin detemir (<1%), insulin aspart (<1%), glinides (0%) and TZDs (<1%). The data suggest annual rates of severe hypoglycemia greater than 1% for NPH, glargine, lispro, glulisine and sulfonylureas. Some of the highest rates of severe hypoglycemia were observed in the intensive control arms of large trials comparing this treatment to conventional control (e.g., ACCORD).

Of the additional 16 studies reviewed to gain a broader population-based perspective on incidence of symptomatic hypoglycemia, 13 were survey studies reporting patient-recalled rates. Eleven of these 13 asked patients to report on events in the past 6 months (N=6) to one year (N=5). In these 11 studies patient reported incidences of hypoglycemia varied widely from 1% to 17%.

## KEY QUESTION #2 What are the risk factors for severe hypoglycemia in adults with type 2 diabetes on one or more hypoglycemic agents (e.g., demographics, co-morbidities, diabetes treatment regimen, other medication use, goal and achieved HbA1c)?

We identified 31 articles on 28 studies that provided information about risk factors for severe hypoglycemia.

### Overview of Included Studies (Appendix E, Table 1)

An overview of the 31 included articles is shown in Appendix E, Table 1. These 31 articles represent 28 unique studies, including four randomized controlled trials,43, 89–91 three prospective cohort studies (in five articles), 16, 17, 92–94 five retrospective cohort studies,25, 95–98 seven cross sectional studies,76, 78, 84, 85, 99–101 seven case control studies,24, 27, 102–106 and three case series,107, 108 one of which was related to a prospective cohort study.17 Although we excluded case series, two studies were originally misclassified and retained in our analyses. Four studies were multinational,3, 4, 85, 107 seven were performed in the United States, three in Germany, three in Scotland, three in the UK, and eight in other countries (Australia, Denmark, Mexico, Sweden, Italy, Japan, Greece, Poland). All of the studies enrolled both men and women. Average age ranged from the mid 50s to the low 80s, with 14 of the studies having an average age in the 60s. Six studies17, 24, 25, 27, 43, 85, 109 were entirely funded by a pharmaceutical company. Funding for nine studies was supplied by government agencies with or without supplementary pharmaceutical company support. Funding for 13 studies was not reported.

Although all 28 studies are included in Appendix E, Tables 4 and 5, in the text below we summarize 14 articles on 12 unique study populations. Sixteen articles were not included in this summary because they did not report multivariate analyses of risk factors. One additional article was excluded since the multivariate analysis evaluated any (not severe) hypoglycemia.24 The 12 studies included two RCTs, one prospective and one retrospective cohort, four cross sectional, and four case control studies.

#### Definition of Severe Hypoglycemia

All 28 studies met our pre-specified minimal definition of severe hypoglycemia as defined in Key Question #1. Of the 12 multivariate adjusted studies, four used HA (Hypoglycemia needing any Assistance), three used HMA (Hypoglycemia requiring Medical Assistance), three used administration of IV glucose, and two studies categorized events by more than one definition.3, 92

#### Quality

The quality of both RCTs was good. Of the non-randomized studies, 9 of 12 met criteria for three or more of the quality metrics (Appendix D, Table 3).

### Results

(See Table 3 and Appendix E, Table 6)

Table 3 Significant Risk Factors for Severe Hypoglycemia

Study, year | Older Age | Male Gender | Nonwhite Race | Married | Advanced Education | Impaired Awareness | Alcohol | Smoking | Lower BMI | Longer Diabetes Duration | Higher HbA1c | Previous Hypoglycemia | Polypharmacy | Renal Disease | Microvascular Complications | Macrovascular complications | Dementia or cogniftive impairment | Intense control | Insulin or insulin dose | Time on insulin | Metformin | Sulfonlyurea or dose | Other
Akram 2006 84 **** | x | | | ↑ | | ↑ | | x | | ↑ | | | | | ↑ | x | | | x | | x | | ↓
Bruce 2009 92 ** | x | | | x | | | | | ↑ | x | | ↑ | | ↑ | x | x | ↑ | | ↑ | | | | ↑
Davis 2010^16,**,***^ | x | x | | | ↑ | | x | | x | x | ↑ | ↑ | | ↑ | ↑ | | | | ↑ | ↑ | | x | ↑
Davis 2011 93 ** | x | x | | | ↑ | | x | | x | x | x | ↑ | x | ↑ | ↑ | | | | x | ↑ | | x | ↑
Duran-Nah 2008 104 | ↓ | | | | ↓ | | | | | ↑ | | ↑ | x | ↑ | | | | | | | | | ↑
Holstein 2009 102 | ↓ | x | | | | | | | x | x | x | | x | x | | | | | | | x | ↑
Holstein 2011 103 | | | | | | | | | | | ↓ | | | | | ↑ | x | | x | | | x | ↑
Miller 2001 100 ****** | x | x | x | | | | | | x | x | x | x | | x | | | | | x | | | x | x
Miller 2010 89 | ↑ | ↓ | ↑↓***** | | ↓ | | x | | ↑ | ↑^*^ | ↑ | | | ↑ | ↑ | x | | ↑ | ↑ | | x | x | ↓
Quilliam 2011 27 | x | ↓ | | | | | | | | | | ↑ | | ↑ | ↑ | ↑ | | | ↑ | | ↓ | ↑ | ↑
Sarkar 2010 78 ******* | x | x | x | | ↓ | | x | | x | x | x | | | x | x | | x | | x | | x | x
Shen 2008 101 ******* | x | x | ↑ | | | | | | | | | | | | | x | x
Shorr 1997 97 | ↑ | ↑ | ↑ | | | | ↑ | | | | | | ↑ | | | | | | ↑ | | | ↑ | ↑
Zoungas 2010 90 | ↑ | x | | | ↓ | | | ↑ | ↑ | ↑ | x | | | ↑ | ↑ | x | ↑ | ↑ | | | x | | ↑

↑ = significantly increase the risk of hypoglycemia in multivariate analysis

↓ = significantly decrease the risk of hypoglycemia in multivariate analysis

X = risk factors included in the multivariate model AND non significant risk factors

Microvascular Disease: microalbuminuria, diabetic eye disease, peripheral neuropathy

Macrovascular Disease: stroke, transient ischemic attack, myocardial infarction, angina, coronary or peripheral revascularization, leg amputation

* Total time since diagnosis of diabetes not significant, but 16+ years ↑

** Data from Fremantle Diabetes Study

*** compiled data from all multivariate models

**** includes both any event and repeated events

***** ↑ for African American, ↓ for “Other”

****** Includes intensive, standard, and combined

******* Only evaluated one risk factor as independent variable

Since the studies varied considerably with respect to risk factors evaluated (and their definitions), populations studied, and lengths of follow-up, the data were considered unsuitable for pooling. We present, instead, a narrative summary. Although [underlined: impaired hypoglycemia awareness] was evaluated in only one study, it is frequently listed as a well-established risk factor so we include it here as well. The single study that met our criteria was a cross sectional survey of 401 subjects, in which impaired awareness was associated with an increased risk of hypoglycemia (OR 2.66, 95% CI 1.55 to 4.56).84 The risk factor [underlined: intensive glycemic control] is discussed above under Key Question #1.

[underlined: Gender] was evaluated as a risk factor in seven studies,16, 27, 89, 90, 97, 100, 102 with mixed findings. Most studies, including the large ADVANCE trial, showed no association between gender and risk for severe hypoglycemia.16, 90, 102 One large retrospective cohort study showed that men were at higher risk than women, but the 95% confidence interval extended to 1.0.^97^ In ACCORD, women were more likely than men to experience a hypoglycemic event requiring medical assistance (HR 1.21, 95% CI 1.02 to 1.43). Similarly, in a nested case-control study using a claims database, men on at least one OHA had a 16% lower risk of hypoglycemia-associated hospitalization than women (OR 0.84, 95% CI 0.73 to 0.96).27

[underlined: Race] was evaluated in four studies, three of which found that blacks are at higher risk for severe hypoglycemia than whites. These studies included one large RCT,89 two retrospective cohort studies,97, 100 and one cross-sectional study.101 ACCORD reported that, compared to non-Hispanic whites, blacks had a 43% increased risk of HMA (HR 1.43, 95% CI 1.2 to 1.7) and that people in racial groups other than Hispanic or black had a lower risk of HMA than whites (HR 0.64, 95% CI 0.47 to 0.88).89 An increased risk for African Americans was also seen in a large population-based retrospective cohort study of 20,000 Medicaid enrollees over age 65 in Tennessee. Specifically, blacks on OHAs had a two-fold increased risk of hypoglycemia-related hospitalization, ED visit or death compared to whites (RR 2.0, 95% CI 1.7 to 2.4).97 A cross-sectional analysis of hospitalizations among people with type 2 diabetes in US community hospitals indicated that blacks were more likely than whites to have a diagnosis of acute hypoglycemic condition (OR 1.62, 95% CI 1.55 to 1.69).101

[underlined: Body mass index] was evaluated in five studies, including two large RCTS, 89, 90 both of which found that a higher BMI was associated with a lower risk of severe hypoglycemia. In ACCORD,89 a BMI of 30 or higher was associated with a 35% lower incidence of HMA than a BMI of less than 25 (HR 0.65, 95% CI 0.5 to 0.85). Similarly, in ADVANCE90 for each unit (kg/m^2^) increase in BMI there was a 5% decrease in risk of HA (HR 0.95, 95% CI 0.93 to 0.98). BMI was not found to be associated with risk in three smaller studies.16, 100, 102

[underlined: Age] was evaluated as a risk factor for severe hypoglycemia in nine studies (two RCTs, one prospective and one retrospective cohort, one cross sectional, and four case control). The two largest trials (ACCORD89 and ADVANCE90) both reported significant associations between older age and risk of severe hypoglycemia. In ACCORD,89 the risk of HMA increased by 3% for each additional year of age (HR 1.03, 95% CI 1.02 to 1.05). ADVANCE90 reported almost identical results (HR 1.05, 95% CI 1.03 to 1.07). Confirming these findings, a population-based retrospective cohort study of 20,000 Medicaid enrollees over age 65 in Tennessee, found that compared to enrollees age 65–69, older age groups had significantly increased risk (age 70–74: RR 1.1, 95% CI 0.9 to 1.4; age 75–79: RR 1.5, 95% CI 1.2 to 1.9; age ≥ 80: RR 1.8, 95% CI 1.4 to 2.3).97 Six smaller studies showed either no significant association between age and risk of severe hypoglycemia16, 27, 84, 100 or a significant [underlined: inverse] association.102, 104

[underlined: Diabetes duration] was evaluated as a risk factor in seven studies (two RCTs, one prospective and one retrospective cohort, two case control, one cross sectional). In ACCORD, compared to people with diabetes duration of 5 years or less, the risk for those with diabetes duration of 11–15 years increased by a non-significant 6% (HR 1.06, 95% CI 0.83 to 1.37) and by 37% for those with diabetes of 16 or more years (HR 1.37, 95% CI 1.09 to 1.73).89 In ADVANCE each year of diabetes was associated with a 2% increase in risk of severe hypoglycemia (HR 1.02, 95% CI 1.00 to 1.04).90 Similar results were reported by the cross sectional84 and one of the case control studies.104 The other three studies did not find statistically duration of diabetes and incidence of severe hypoglycemia.16, 100, 102

[underlined: Previous hypoglycemia] was evaluated as a risk factor in four studies, two case control,27, 104 one prospective,16 and one retrospective cohort.100 Three studies found that a history of past hypoglycemia was a strong predictor of future episodes, and one did not.100 In a large case control study based on administrative data, a prior emergency room (ER) visit for hypoglycemia increased the odds of a subsequent inpatient admission for hypoglycemia by more than nine-fold (OR 9.5, 95% CI 5 to 18).27 In the other case control study a reported history of hypoglycemia, not further defined, in the previous year was associated with a three-fold increase risk of hypoglycemia associated hospitalization or ER visit (OR 2.9, 95% CI 1.3 to 6.5).104 History of previous episode requiring health services use was associated with a six-fold increase for another episode over the next 8 years (HR 5.7, 95% CI 2.2 to 15) in the prospective cohort study.16

[underlined: Education] was evaluated as a risk factor in five studies, two RCTS,89, 90 one cross sectional,78 one case control104 and one prospective cohort study.16 Four of the five studies found significant but modest associations between level of education and risk for severe hypoglycemia. ADVANCE found a marginally significant inverse association between the age at completion of formal education and risk of severe hypoglycemia (HR 0.98 95% CI 0.96 to 1.0).90 Similarly, in ACCORD, subjects with less than a high school education were at an increased risk for severe hypoglycemia (conventional control: HR 1.74, 95% CI 1.02 to 2.95; intensive control: HR 1.38, 95% CI 1.06 to 1.81) compared to those with more education.89 In the case control study, illiteracy was associated with an increased risk (OR 3.7, 95% CI 1.4 to 10).104 In a cross sectional study in a community population, Sarkar et al. found that subjects who indicated that they had “problems learning,” “needed help reading,” or “lacked confidence with forms” were about 30– 40% more likely to have reported an HA in the previous year.78 Finally, in the prospective cohort study, “education level higher than primary level” was associated with an increased risk of severe hypoglycemia (HR 2.3, 95% CI 1.09 to 5.04, N=616).16

[underlined: Renal disease] was evaluated as a risk factor in seven studies, two RCTs,89, 90 one prospective,16 one retrospective cohort100 study, and three case control studies.27, 102, 104 Five of these studies found that renal insufficiency (defined as elevated serum creatinine level or elevated estimated glomerular filtration rate) was significantly associated with increased risk of severe hypoglycemia. The only studies that did not find a significant association were a very small study,102 and the retrospective cohort study that was conducted in a single institution with a predominantly African American population.100 In ACCORD, a urine albumin:creatinine ratio greater than 300 or a serum creatinine greater than 115 umol/L were each associated with a significantly increased risk of about 70%. In ADVANCE, for each umol/L increase in serum creatinine, the risk of a severe hypoglycemic event increased by 1%.90

[underlined: Other (non-renal) microvascular disease] was assessed in five studies. 16, 27, 84, 89, 90 In four of the five there were significant positive associations; in one relatively small study (N=415), which evaluated untreated retinopathy and symptomatic or asymptomatic peripheral neuropathy, there were no statistically significant associations for any event, but peripheral neuropathy was found in increase the risk of repeated events of severe hypoglycemia.84 In ACCORD a history of peripheral neuropathy conferred a modest but significant increased risk (HR 1.2, 95% CI 1.1 to 1.4).89 In ADVANCE a “history of microvascular disease” conferred a twofold increased risk of severe hypoglycemia (HR 2.1, 95% CI 1.5 to 3.).90 In a nested case-control database study, peripheral ulceration was found to be positively associated with risk of inpatient hospital admission for hypoglycemia (OR 1.71, 95% CI 1.2 to 2.44).27 Finally a population based but relatively small study (N=616) found that a history of peripheral neuropathy was significantly associated with severe hypoglycemia (HR 2.4, 95% CI 1.3 to 4.5).16

[underlined: Dementia] was evaluated as a risk factor for severe hypoglycemia in three studies.90, 92, 103 In ADVANCE, higher cognitive function as measured by the Mini Mental Status Examination was significantly associated with a modest decreased risk of severe hypoglycemia (HR 0.93, 95% CI 0.87 to 0.99).90 In the second study, which was population based and prospectively followed 302 patients age 70 years and older, patients with dementia at baseline had a significantly higher risk for hypoglycemia requiring medical attention than those who did not have dementia (HR 3.0, 95% CI 1.1 to 8.5).92 In a small case control study, dementia was not found to be a significant risk factor.103

[underlined: Other risk factors evaluated in the 12 studies] included genetic markers, marital status, smoking, alcohol consumption, polypharmacy, recent discharge from the hospital, and use of ACE inhibitors. All were found, in one or more studies, to be associated with increased risk of hypoglycemia (See Appendix D, Table 6). However, these findings were generally sparse, often conflicting, and ultimately inconclusive.

### Summary of Key Question #2

Factors most consistently and independently associated with risk for severe hypoglycemia in adult patients with type 2 diabetes on hypoglycemic medication include: intensive glycemic control (discussed above under Key Question #1), history of hypoglycemia, renal insufficiency, history of microvascular complications, longer diabetes duration, lower education level, African American race and history of dementia. History of hypoglycemia unawareness was evaluated in only one study. Gender, age and lower BMI were not consistently associated with risk, although higher age and lower BMI were associated with higher risk in the two largest studies.

## KEY QUESTION #3 What is the effect of severe hypoglycemia on other outcomes in adults with type 2 diabetes on one or more hypoglycemic agents (e.g., quality of life, mortality, morbidity, utilization)?

We identified 59 articles on 53 studies that provided information about outcomes in patients who experienced severe hypoglycemia.

### Overview of Included Studies (Appendix E, Table 1)

An overview of the 59 included articles is provided in Appendix E, Table 1. Among the 53 studies were 14 randomized controlled trials,3–5, 21, 30, 41, 42, 46, 52, 54, 110–113 16 cohort studies,17, 19, 25, 26, 75, 92, 94–97, 114–118 12 cross sectional studies,78, 81, 82, 99, 119–126 and 11 case control or case series studies.9, 28, 105, 107–109, 127–131 Twelve studies were multinational; additionally, twelve were performed in the United States, four in Germany, three in the UK, three in Scotland, three in Sweden, and the remainder in other countries (Canada, Australia, Singapore, India, Israel, Netherlands, Turkey, Switzerland, France, Italy, Greece, and Poland). All but one of the studies30 enrolled both men and women. Average age ranged from 30 to 85 years with most studies reporting a mean age in the 50 or 60 year range. Twenty one studies were entirely funded by a pharmaceutical company while eight studies were funded by government agencies, three by private foundations, and five by multiple funding sources. No source of funding was listed for 16 studies.

### All-Cause Mortality

All-cause mortality associated with severe hypoglycemia was reported in three large randomized trials that compared intensive control to conventional control.3, 4, 21, 61, 90 Mortality ranged from zero to 12.5 percent in intensively treated people who became hypoglycemic; in two of these three studies mortality in this group was 0.1% or less and in the third there was one death in eight study subjects (12.5%). In all three randomized trials, mortality in the conventional control groups ranged from 0% to 1.2%.

Six additional randomized trials (typically fewer than 1,000 patients enrolled with follow-up less than 30 weeks) compared different treatment regimens, including oral medications and different forms of insulin.42, 43, 46, 52, 111–113 No deaths related to severe hypoglycemia were reported in these studies.

Eight cohort studies reported mortality outcomes, typically in patients seen in an ER or hospitalized for severe hypoglycemia. There were no deaths in three studies.16, 17, 116 In four other studies, between 0.3% and 8.3% of the patients died following severe hypoglycemic events.95–97,98 One study of veterans with and without CKD did not report number of deaths but reported odds ratios for outpatient risk of death within one day of a hypoglycemic event (defined as glucose <50 mg/dl) compared to individuals with glucose of ≥70 mg/dl.75 For patients without CKD, the odds ratio was 13.28 (95% CI 9.30 to 19.18). For patients with CKD, the odds ratio was 6.84 (95% CI 4.41 to 10.62).

Mortality was also assessed in six case series. As with the cohort studies, these studies also enrolled patients seen in an emergency room or admitted to a hospital as a result of severe hypoglycemia. Four studies reported no deaths.28, 108, 109, 128 Three other studies reported that between 3.2% and 11% of the enrolled patients died after severe hypoglycemia.105, 127, 131

Three studies reported long-term follow-up mortality data. Participants in the ADVANCE trial were followed for a median of 5 years.90 The mortality rate was 19.5% in those who had experienced at least one episode of severe hypoglycemia and 9.0% in those who had not (adjusted HR 3.27, 95% CI 2.29 to 4.65). The median time to death was 1.05 years. In a prospective cohort study, there were no deaths at the time of the event but 16 of the 45 patients (35.6%) died during the mean follow-up period of 22.8 months.17 The third study, a retrospective cohort study that observed in-hospital mortality of 1.6% (2 of 126 patients), reported long-term mortality of 42.1% (53 of 126 patients) during a median follow-up of 23.2 months. Of the 53 total deaths, 20 were in the group of patients treated with oral medications and 33 were in the group treated with insulin (univariate analysis, p=0.02).95 The authors reported that median annual mortality in the study population was 22% and compared that to 5.2% in the general population (patients with and without diabetes, age 80 years).

### Non-fatal Myocardial Infarction

Three randomized trials, one cohort study, and one case series provided information about non-fatal myocardial infarctions among patients with severe hypoglycemia. Two randomized trials reported no events.30, 113 The third reported that one patient (4.5%) experienced severe hypoglycemia with cardiac arrest.110 The authors did not say how much time elapsed between the hypoglycemic episodes and the cardiac arrests. A cohort study that enrolled individuals who experienced severe hypoglycemia reported three cases (0.5%) with myocardial infarction as a complication of the hypoglycemia.97 A case series reported two cases (2%) of transient asymptomatic myocardial ischemia associated with severe hypoglycemia.127

### Non-fatal Stroke

Non-fatal stroke outcomes were reported in four studies. A randomized trial of several hypoglycemic therapies reported no stroke events.113 A cohort study with 586 patients reported seven patients (1.2%) experiencing stroke as a complication of severe hypoglycemia.97 A case series of 207 patients admitted to a hospital with severe hypoglycemia during a three year period, included two patients (0.97%) who experienced cerebrovascular ischemic stroke.108 In a case series of 19 patients with severe hypoglycemia associated with glipizide use (over a 7 year period), one patient (5.3%) who had a stroke prior to the hypoglycemic event experienced further functional impairment. The patient died 23 days after the event.105

### Other Neurologic Events

Two randomized trials with veterans assigned to either intensive or conventional control reported data on other neurologic events associated with severe hypoglycemia. In one trial, loss of consciousness was reported for both of the conventional control group patients who experienced severe hypoglycemia (2.6% of the conventional control group) and none of the five intensive control patients who experienced severe hypoglycemia (0% of the intensive control group).30 In the second trial, severe hypoglycemia with impaired consciousness was reported in three episodes/100 patient-years in the conventional control group compared to nine episodes/100 patient-years in the intensive control group. In addition, complete loss of consciousness was reported in one episode/100 patient-years and three episodes/100 patient-years, respectively. Both differences were significant (p<0.001). The median follow-up in the trial was 5.6 years. 5

Five randomized trials of different treatment regimens also reported neurologic outcomes. Two trials reported zero events.41, 54 In another trial, at the three year follow-up, loss of consciousness associated with severe hypoglycemia was reported by four patients – one in the biphasic aspart group (0.4%) and three in the basal detemir group (1.3%).43 One trial reported one patient with a coma (0.5%) among 199 treated with NPH plus regular human insulin.112 In the last trial, seven episodes in four patients either required medical assistance or were accompanied by neurological symptoms.52

Three cohort studies provided data on neurologic outcomes. One study reported that, at presentation to a hospital, 51% were in a coma, 18% were disoriented, 11% experienced somnolence, 9% experienced paralysis, 7% had cerebral seizures and 5% had psychological disturbances.17 In another study, among 126 patients admitted for severe hypoglycemia, 54% of oral hypoglycemic agent users experienced coma compared to 30.2% of insulin users.95 A third study reported transient ischemic attack as a complication of severe hypoglycemia in four patients (0.7%).97 At presentation, a loss of consciousness was observed in 49% of episodes, seizures in 5% of episodes and irrational behavior in 6% of episodes.97

Seven other studies reported on this outcome. A cross-sectional study reported that 4% of patients experienced convulsions associated with episodes of severe hypoglycemia in the past year.99 In five case series, coma was reported in 19% to 71% of individuals with severe hypoglycemia.105, 107, 108, 128 “Semi-coma” (30%),108 coma or stupor (21%),28 somnolence (51%),128 decreased consciousness (16%),105 seizures (8–10%),107, 127 disorientation (81%),107 and transient right hemiplegia (1%)127 were also reported. One study documented seizures and/or psychological disturbances in 30% of patients with severe hypoglycemia.128

### Hospitalization

Five randomized trials reported hospitalization data. One trial of intensive versus conventional control among veterans reported no hypoglycemia-associated hospitalizations.30 Four trials of different treatment regimens found between 0%^41, 42, 113, 132^ and 0.8%^112^ were hospitalized for hypoglycemia.

Hospitalizations were also reported in nine cohort studies (10 papers). Among patients starting insulin, there were no hospitalizations in 9970 patient years of observation.26 A study of 344 veterans followed for one year identified 55 severe hypoglycemic episodes in 19 subjects; two of these (3.6%) required hospitalization.19 A mean hospitalization rate of 0.15 episode/patient/year was reported for type 2 patients based on data from 21 patients with 29 severe hypoglycemic episodes.116 A hospitalization rate of 47 per 1000 person-years was reported based on data from all discharges from Navajo Area Indian Health Service hospitals during a 5 year period with an estimated 26,125 person-years of observation.96 A study that included both type 1 and type 2 patients reported that over a mean follow-up of 2.5 years, insulin-treated individuals with diabetes who had hypoglycemic episodes had more overall hospital admissions (0.97 per year vs. 0.48 per year in insulin-treated individuals without hypoglycemic episodes, p<0.01). Forty percent of the excess hospital admissions were due to hypoglycemia.118

Three other cohort studies (four papers) reported hospitalization associated with 17% to 33% of hypoglycemic events25, 114, 133 or 7.1% of patients experiencing hypoglycemia.117 Another study reported that 16% of patients seen in the emergency department were subsequently admitted to the hospital.115

In a cross-sectional study of patients with type 2 diabetes from a large diabetes registry, 8% of the patients with a self-reported significant hypoglycemia episode had a documented emergency room visit or hospitalization. The odds of an emergency room visit or hospitalization were significantly higher in patients who reported having at least one significant hypoglycemia episode (OR 19.0, 95% CI 13.0 to 26.0) compared to those without a significant hypoglycemia episode.78 One other cross-sectional study reported no hospitalizations125 while a second reported that 5.5% of patients were treated in an emergency department or hospitalized following severe hypoglycemia.124

Length of hospital stay, reported in two case series, ranged from a median of 5.5 days128 to means of 9.8 days for patients on oral medications and 8.0 days for patients taking insulin.95

### Emergency Department Visits

Two randomized trials reported that no patients with severe hypoglycemia required an emergency department visit.42, 113 A third randomized trial reported that either 0% (insulin glargine group) or 15.4% (NPH group) of those with severe hypoglycemia were seen in the emergency department.41, 132

Four cohort studies reported emergency department use. One study reported that between 14% and 23% of severe hypoglycemic episodes were treated in the emergency room.114, 133 Another cohort study reported that 31% of the patients enrolled, all of whom were eventually hospitalized, were treated first in the emergency department17 while a third found that 8% of patients were treated in either the emergency or primary care service, 36% were treated by an ambulance service and 55% required both ambulance and emergency or clinic service.25 Finally, over a mean follow-up of 2.5 years, insulin-treated diabetic individuals who experienced hypoglycemic episodes had higher rates of overall emergency department use (0.85 visits per year vs. 0.40 visits per year in insulin-treated diabetic individuals who did not have a hypoglycemic episode, p<0.01) with 53% of the excess visits due to hypoglycemia.118

Two cross-sectional studies (noted above) reported on rates of either hospitalization or emergency department visit (5.5% to 8%).78, 124 An additional cross-sectional study reported that six of the seven patients with severe hypoglycemia during a one month period required medical services including three emergency room visits.125

### Accident/Trauma

An evidence report prepared for the Federal Motor Carrier Safety Administration (FMCSA)134 focused on the risk of motor vehicle crashes in drivers with diabetes and the relationship with hypoglycemia. Based on data from 13 case-control studies of low to moderate quality, the conclusion was that the risk for crash among drivers with diabetes was higher than for those without diabetes (RR 1.19, 95% CI 1.08 to 1.31). Many of the studies enrolled only patients with type 1 diabetes and all but two were published before 2000. The strength of evidence was rated as weak. To look at the effect of hypoglycemia on driving ability, the review identified three studies of moderate quality, all with type 1 patients. All three involved induced hypoglycemia and simulated driving ability. Although driving ability was impaired, it was unclear which aspects of driving ability were most affected or at what level of hypoglycemia the impairments were evident. It is unknown whether data from driving simulators are predictive of crash risk in actual driving conditions.

We identified several other studies related to motor vehicle operation that were either not included in the FMCSA review or were published after the review was completed. A case-control study identified 795 drivers who were reported (typically because of a motor vehicle crash, mandatory annual review for commercial vehicle license, license suspension appeal, or notifiable medical condition) to the Ontario Ministry of Transportation Medical Advisory Board and who had an underlying diagnosis of diabetes mellitus. The type of diabetes was not reported. Among the cases (57 drivers who had a crash), 60% reported experiencing severe hypoglycemia in the past 2 years compared to 27% of the controls (738 drivers with no crash) (OR 4.07, 95% CI 2.35 to 7.04). A lower HbA1c was also associated with an increased risk of crash even after adjusting for severe hypoglycemia (OR 1.25, 95% CI 1.02 to 1.55).129 A cross-sectional study of diabetic patients taking hypoglycemia-inducing medications found that among the 122 patients talking oral-antidiabetics (116 with type 2 diabetes, mean age 64.2 years), subjects reported two hypoglycemia-induced accidents per year driven. Among the 151 patients receiving conventional insulin therapy (109 with type 2 diabetes, mean age 59.0 years, treated with one or two injections of premixed insulin and may also be taking other oral antidiabetics), there were three hypoglycemia-induced accidents per year driven. When asked if they refrained from driving due to fear of hypoglycemia events during driving, 0.8% of the oral medication group and 4.0% of the conventional insulin therapy group responded “yes.”121

Several studies reported on motor vehicle accidents but did not specifically relate the outcome to severe hypoglycemia. In the ACCORD study, there was no difference in incidence of motor vehicle accidents in which the patient was the driver (0.2% in intensive therapy, 0.3% in standard therapy, p=0.40).3 A nested case-control study used an insurance registry of all eligible drivers ages 67 to 84 years, an accident report file, and a prescription drug database. The type of diabetes was not reported. Several medication regimens were associated with a borderline significant risk of an accident. A combination of sulfonylureas and metformin was used during the preceding month by 1.6% of those involved in a crash and 1.2% of the controls (adjusted rate ratio 1.3, 95% CI 1.0 to 1.7). The adjusted rate ratio for any insulin use was 1.3 (95% CI 1.0 to 1.8). A dose-response effect was noted for users of a combination of sulfonylureas and metformin over the year preceding the index event.135

Six studies reported falls and bone injury data.17, 95, 97–99, 127 A cohort study of 45 patients with sulfonylurea-induced hypoglycemia requiring hospitalization reported that six (13%) had soft tissue injuries or fractures as a result of falls associated with hypoglycemia.17 A second cohort study of 126 type 2 diabetic patients hospitalized for severe hypoglycemia found that the percentage of patients who had experienced a fall was 21.5% with no difference between oral medication and insulin users.95 In a third cohort study, among patients hospitalized for severe hypoglycemia, bone injuries were reported in 7.3% of patients (9.9% of the insulin users, 0% of the oral medication users).98 A cohort study97 and a cross-sectional study99 reported “injury” in 1.7% to 5% of patients who experienced severe hypoglycemia. In a case series brain trauma and skeletal injury were reported in 7% of patients.127

### Quality of Life

Nine cross-sectional studies reported measures of quality of life. One study assessed health-related quality of life with the SF-36 and reported that scores for all domains were lowest for patients reporting severe hypoglycemia.120

Five studies (reported in six papers) assessed health utility/quality of life with the EuroQol-5 Dimensions (EQ-5D). EQ-5D scores were lower for patients reporting severe hypoglycemia.81, 82, 87, 119, 120, 126 Three studies reported data from the worry subscale of the Hypoglycemia Fear Survey-II (HFS-II). In two studies worry scores were highest for patients who reported severe/very severe symptoms compared to those with lesser symptoms81, 126 while in the third study, there were no differences in worry score as severity increased.82 Both the quality of life and the worry scores were impacted by the frequency of severe hypoglycemia episodes.87

Two studies looked at anxiety and depression associated with severe hypoglycemia.122, 123 In one study, affective disorder, but not anxiety disorder, was found to be associated with a history of severe hypoglycemia in the prior 12 months.122 The second study found that a lifetime history of at least one episode of severe hypoglycemia was associated with symptoms of anxiety (p<0.001) but not depression.123

Lifestyle changes made following an episode of severe hypoglycemia were the focus of one study.124 Patients reported more frequent testing of blood glucose, changes to insulindoses, greater fear of hypoglycem a, requests to have someone check on them, and additional concerns about driving.

### Other Outcomes

#### Cognitive Decline

Cognitive decline was reported in two cohort studies. One of the studies followed patients to determine if the risk of dementia was increased in those with at least one episode of hypoglycemia requiring hospitalization or an emergency room visit.94 Patients who had experienced at least one episode of hypoglycemia during a 22 year period were evaluated for an additional mean of 3.8 years to determine whether they developed dementia. No patient had a diagnosis of dementia, mild cognitive impairment or general symptom memory loss at the time of the hypoglycemic episode(s). Among 1465 patients, the incidence of dementia was higher for patients who had at least one episode of hypoglycemia than for those who had no episodes (17% vs. 10%, p<0.001). The attributable risk of dementia in patients with one or more episodes of hypoglycemia was 2.4% per year (95% CI 1.7 to 3.0). In the adjusted model all patients with at least one episode of severe hypoglycemia were at increased risk for dementia (hazard ratio 1.4, 95% CI 1.3 to 1.7 for one or more episodes).

In the second prospective study, a baseline assessment (the Mini-Mental State Examination and the Informant Questionnaire for Cognitive Decline in the Elderly) was completed on 302 patients age 70 and over. At 18 months, a repeat assessment was done on 205 patients (29 had died, 27 had developed dementia and 41 declined the assessment). Thirty-three new cases of cognitive decline were identified (four cases of dementia and 29 cases of cognitive impairment without dementia). There was no significant difference in prior severe hypoglycemia (either self-reported or requiring medical assistance) between those who developed cognitive decline and those who did not.92

#### Productivity

One cohort study and two cross-sectional studies reported on productivity. In the cohort study, insulin-treated patients with a medical claim coded for hypoglycemia were more likely to use short-term disability (47% vs. 32%, p<0.01) and to use more sick days (19.5 vs. 11.0, p<0.01) than insulin-treated patients with no claim for hypoglycemia. The analysis included patients with either type 1 or type 2 diabetes.118 In one cross-sectional study, a mean loss of 8.6 productive days following hypoglycemia was reported for patients who experienced severe hypoglycemia; for those with mild or moderate hypoglycemia, the mean days lost was 2.7. In multivariate modeling, severity of hypoglycemia (along with frequency) was a significant predictor of productivity.120 A second study reported that 32% of patients who experienced severe hypoglycemia went home from school, work or other activities and 26% stayed home the next day.124

#### Medical Resource Use

Several studies reported on medical service use other than hospitalization or emergency room visits. A randomized trial reported that one of five patients on liraglutide (20%) who experienced severe hypoglycemia required medical assistance of some type.54 One cohort study reported that 1.9% of the 2,417 patients studied required medical contact for hypoglycemia during the first year of insulin use. The number decreased to 0.4% by the fourth year of use.26 A cross-sectional study reported mean total resource use of 13.2 contacts with a health service provider among patients who reported severe hypoglycemia. For patients with mild or moderate hypoglycemia, the mean was 11.5 contacts.120 A second cross-sectional study reported eight nurse visits, three physician visits and one telephone contact with medical care among six patients who experienced severe hypoglycemia in a one-month period (number of events not reported).125 Another cross-sectional study reported that 2.5% of the patients experiencing severe hypoglycemia had additional visits to their physicians while 0.4% had additional communication (non-visit).124 Two studies114, 133 that reported hypoglycemic events before and after conversion to a pen device reported significantly fewer physician visits (37.7% of hypoglycemic events before, 28.1% after; OR 0.39, 95% CI 0.24 to 0.64), no significant difference in outpatient visits (7.8% before, 12.2% after, OR 0.79, 95% CI 0.31 to 2.01), and significantly lower use of “other” (not emergency department, hospitalization, physician visits, or outpatient visits) health care resources (22.1% before, 16.5% after, OR 0.38, 95% CI 0.20 to 0.71) after conversion to the pen device.

### Summary of Key Question #3

We found good evidence for an increased risk of the following outcomes in patients who have experienced severe hypoglycemia: all-cause mortality, neurological events (other than non-fatal stroke), hospital and emergency department utilization and decreased quality of life. Severe hypoglycemia does not appear to be associated with short-term mortality. However, a history of severe hypoglycemia may contribute to increased long-term mortality. Neurological events, including coma, impaired consciousness, seizures and paralysis, were reported in seven randomized trials, three cohort studies and seven other studies. Few patients in the randomized trials experienced coma or loss of consciousness. However, in observational studies of patients presenting to an emergency department or admitted to a hospital, between 19% and 71% were in a coma. Hospitalization and emergency department utilization was reported in five randomized trials, nine cohort studies and three other studies with wide variation across studies. Although many of these studies lacked control groups, there is some evidence of increased emergency department visits and hospital admissions among patients who experience severe hypoglycemia. Data from eight cross-sectional studies suggest that patients who experience severe hypoglycemia generally report a lower quality of life and higher worry.

We found limited data about many of our outcomes of interest including non-fatal MI, non-fatal stroke, cognitive decline, motor vehicle accidents, falls and traumatic injuries, work productivity and other medical service utilization. The available evidence suggests that non-fatal MI and stroke are unlikely consequences of severe hypoglycemia. There are mixed findings from two studies on development of cognitive decline or dementia in individuals with a history of severe hypoglycemia. Few studies have reported motor vehicle accident data specifically related to severe hypoglycemia. Falls and injuries are common consequences of severe hypoglycemia but given the absence of appropriate control groups it is unclear if these outcomes are hypoglycemia-related or simply reflect the age and co-morbidity burden of the population. The evidence suggests that individuals who experience episodes of severe hypoglycemia are more likely to miss days at work. Medical resource utilization findings are difficult to interpret without appropriate control group data.