# FOREST PLOTS FOR KEY QUESTION #1

Appendix F, Figure 1 Severe hypoglycemia event rates for insulin glargine studies*

^*^ Alone or added to OHAs

Appendix F, Figure 2 Severe hypoglycemia event rates for insulin detemir studies

Appendix F, Figure 3 Severe hypoglycemia event rates for NPH insulin studies

Appendix F, Figure 4 Severe hypoglycemia event rates for NPH insulin studies*

^*^ NPH insulin as either primary therapy or in combination (Frische, sulfonylurea; Riddle oral OHAs; Rayman and Dailey, glulisine or regular insulin)

Appendix F, Figure 5 Severe hypoglycemia events, NPH insulin versus insulin glargine studies^*^

Appendix F, Figure 6 Severe hypoglycemia event rates for insulin lispro studies

Appendix F, Figure 7 Severe hypoglycemia event rates for insulin aspart studies

^*^ Subjects may also have received OHAs in addition to insulin aspart.

Appendix F, Figure 8 Severe hypoglycemia event rates for insulin glulisine (+NPH insulin) short-term (26 wks) studies

Appendix F, Figure 9 Severe hypoglycemia rates for sulfonylurea studies*

^*^ Sulfonylurea monotherapy and combined sulfonylurea and metformin studies

Appendix F, Figure 10 Severe hypoglycemia events for BARI 2D study, insulin sensitization versus insulin provision

Appendix F, Figure 11 Severe hypoglycemia events for intensive glycemic control versus usual care studies