# EVIDENCE TABLES

Table 1 Characteristics of Included Studies

Table 2 Characteristics of Studies Included in Extended Analysis for Key Question #1

Table 3 Incidence of Severe Hypoglycemia by Treatment Arms

Table 4 Risk Factor Data Table for Key Question #2

Table 5 Risk Factors for Severe Hypoglycemia Reported in the Individual Studies

Table 6 Other Risk Factors in Multivariate Studies

Table 7 Clinical Outcomes in Patients with Severe Hypoglycemia

Table 8 Other Outcomes in Patients with Severe Hypoglycemia