# STUDY QUALITY TABLES

Table 1 Individual Study Quality for KQ1, Randomized Studies

Study | Allocation concealment | Blinding | Intention-to treat analyses | Withdrawals adequately described | Quality
Abraira (VA-CSDM) 1995 30 | Unclear | Outcomes/endpoints | No | Yes | Fair
ACCORD 2008, 2011^3, 7^ | Adequate | Outcomes/endpoints | Yes | Yes | Good
ADVANCE 2008 4 | Adequate | Outcomes/endpoints | Yes | Yes | Good
Anderson 1997 47 | Unclear | No | Yes | No | Fair
Arechaveleta 2011 52 | Unclear | Yes (double) | Yes | Yes | Fair
Aschner 2006 136 | Unclear | Yes (double) | Yes | Yes | Fair
Aschner 2010 60 | Unclear | Yes (double)^*^ | No | Yes | Fair
BARI 2D 58 | Unclear | Outcomes/endpoints | Yes | Yes | Fair
Barnett 2008 171 | Adequate | No | Yes | Yes | Fair
Bolli 2008 and 2009^172, 173^ | Unclear | Yes (double) | Yes | Yes | Fair
Buse 2009, 2011^36, 110^ | Adequate | Outcomes/endpoints | Yes | Yes | Good
Chou 2008 55 | Unclear | Yes (double) | No | Yes | Fair
Dailey 2004 46 | Unclear | No | Yes | Yes | Fair
Davies 2005 38 | Unclear | No | No | Yes | Fair
Dormandy (PROactive) 2005 174 | Adequate | Yes (double)^*^ | Yes | Yes | Good
Drouin 2004 32 | Unclear | Yes (double) | No | Yes | Fair
Duckworth (VA-DT) 2009 5 | Adequate | Outcomes/endpoints^*^ | Yes | Yes | Good
Fritsche 2003 44 | Adequate | No | No (2excluded) | Yes | Fair
Garber 2011 51 | Adequate | Yes (double) | No (1excluded) | Yes | Good
Haak 2005 33 | Adequate | No | Yes | Yes | Fair
Heine 2005 42 | Adequate | No | No | Yes | Fair
Holman 2009, 2007^43, 111^ | Adequate | Outcomes/endpoints | No (1excluded) | Yes | Good
Kendall 2005 56 | Unclear | Yes (double) | No (1excluded) | Yes | Fair
Kennedy 2006 37 | Adequate | No | No | Yes | Fair
Liebl 2009 PREFER 48 | Unclear | No | No | Yes | Fair
Marre 2009 175 | Unclear | Yes (double) | No (1excluded) | Yes | Fair
Matthews 2010 49 | Unclear | Yes (double) | No | Yes | Fair
Meneghini PREDICTIVE 2007 176 | Unclear | No | No | Yes | Fair
Nauck 2009 177 | Adequate | Yes (double) | No (2 excluded) | Yes | Good
Olansky 2011 178 | Unclear | Yes (double) | No | Yes | Fair
Pratley 2010 179 | Adequate | Outcomes/endpoints | No (7excluded) | Yes | Good
Raskin 2009 31 | Unclear | No | Yes | Yes | Fair
Ratner 2002 34 | Unclear | Yes (double) | No | Yes | Fair
Rayman 2007 45 | Unclear | No | No | Yes | Fair
Riddle 2003, Dailey 2009^41, 132^ | Adequate | Outcomes/endpoints | No | Yes | Fair
Rosenstock 2001 39 | Unclear | No | Yes | Yes | Fair
Rosenstock 2008 40 | Adequate | No, open-label | No | Yes | Fair
Rosenstock 2009 35 | Unclear | No | No | Yes | Fair
Russell-Jones 2009 54 | Adequate | Double^*^(insulin arm open-label) | No | Yes | Good
Saloranta 2002 59 | Unclear | Yes (double) | Unclear | No | Fair
Schernthaner 2004 57 | Unclear | Yes (double) | No | Yes | Fair
Seck, 2010, Nauck 2007^50, 177^ | Unclear | Yes (double) | No | Yes | Fair
Standl 2006 180 | Unclear | No | No | Yes | Fair
UKPDS 33 21 | Adequate | Unclear | Yes | No | Good
Williams-Herman 2009, Goldstein 2007^113, 181^ | Unclear | Yes (double)^*^ | No | Partially | Fair
Zinman 2009 182 | Adequate | Yes (double) | No (3 excluded) | Yes | Good

* plus end points adjudicated by blinded committee

Table 2 Individual Study Quality for KQ1, Non-Randomized Studies

Study | Design | Population of interest | Outcomes assessed and reported | Measurement same for all subjects | Confounding controlled
Asche 2008 23 | Retrospective cohort | Yes | Yes | Yes | Yes
Berntorp 2011 15 | Prospective cohort | Yes | Yes | Yes | No
Bodmer 2008 24 | Retrospective cohort with nested case/control | Yes | Yes | Yes | Yes
Davis 2010 16 | Prospective cohort | Partially^*^ | No | Yes | Yes
Holstein 2001 17 | Prospective cohort | Yes | Yes | Yes | Yes
Leese 2003 25 | Retrospective cohort | Yes | Yes | Yes | No
Marre 2009 (PREDICTIVE) 18 | Prospective cohort | Partially^*^ | Yes | Yes | No
Murata 2005 19 | Prospective cohort | Yes | Yes | Yes | No
Nichols 2010 26 | Retrospective cohort | Yes | Yes | Yes | No
Pencek 2009 20 | Prospective cohort | Yes | Yes | Yes | No
Quilliam 2011 183 | Retrospective cohort | Yes | Yes | Yes | Yes
Stahl 1999 28 | Retrospective case series | No | Yes | Yes | Yes
UK Hypoglycaemia Study Group 21 | Prospective cohort | Yes | Yes | No | No
Valensi 2009 IMPROVE 22 | Prospective cohort | Yes | Yes | Yes | Yes

* Included diabetes type 1

Table 3 Individual Study Quality for KQ2, Randomized and Non-Randomized Studies

RANDOMIZED CONTROLLED TRIALS
Study | Allocation concealment | Blinding | Intention-to treat analyses | Withdrawals adequately described | Quality
ACCORD Miller 2010 89 | Adequate | Outcomes/endpoints | Yes | Yes | Good
ADVANCE Zoungas 2010 90 | Adequate | Outcomes/endpoints | Yes | Yes | Good

NON-RANDOMIZED TRIALS
Study | Design | Population of interest | Outcomes assessed and reported | Measurement same for all subjects | Confounding controlled
Akram 2006 84 | Cross-sectional survey | No | Yes | No | Yes
Bruce 2009 92 | Prospective cohort | No | No | No | No
Davis 2010 16 | Prospective cohort | Partially^*^ | No | Yes | Yes
Davis 2011 93 | Prospective cohort | Partially^*^ | Yes | No | Yes
Duran-Nah 2008 104 | Case-control | No | Yes | Yes | Yes
Holstein 2009 102 | Case-control | No | Yes | Yes | Yes
Holstein 2011 103 | Case-control | No | Yes | Yes | Yes
Miller 2001 100 | Cross-sectional | Yes | Yes | Yes | Yes
Quilliam 2011 27 | Nested Case-control | Yes | No | Yes | Yes
Sarkar 2010 78 | Cross-sectional | Yes | Yes | No | Yes
Shen 2008 101 | Cross-sectional | Yes | Yes | Yes | Yes
Shorr 1997 97 | Retrospective cohort | Yes | Yes | Yes | Yes

* Included diabetes type 1