# CRITERIA USED IN QUALITY ASSESSMENT OF NON-RANDOMIZED STUDIES

We evaluated each non-randomized trial based on the five elements below. To be considered low risk of bias for any element, a “yes” response was required for each of the questions (a, b, c) pertaining to the element, if applicable. Plots were developed to show the percent of the non-randomized trials in each area (human resources practices, organizational culture, and physical environment) that were assigned a yes (met criteria) or no (failed to meet criteria) for each element.

1. Population
  a. Is the sample representative of the population of interest?
  b. Did researchers apply inclusion/exclusion criteria uniformly to all comparison groups and is the selection of the comparison group appropriate?
  c. Is the sampling method appropriate (i.e., appropriate database or sample for research question, adequate response rate for survey studies, etc.)?
2. Outcomes
  a. Are important outcomes assessed and reported (i.e., not just intermediate or surrogate outcomes)?
  b. Was the length of follow-up appropriate for the research questions (consider benefits and harms)?
  c. Is the impact of loss to follow-up (or differential loss to follow-up) considered in the analysis?
3. Measurement
  a. Are outcome, predictor and covariates assessed in the same way for everyone?
  b. Is this blinded such that, for example, a person’s exposure status would not be known at the time outcome status was assessed? This is where recall bias and other types of differential assessment come into play.
  c. Are the tools used to assess exposures and outcomes accurate and reliable (i.e., are standard measures used)?
4. Confounding
  a. Are the statistical methods and study design adequate for minimizing confounding?
  b. Aside from the exposure of interest, are groups balanced in terms of factors that might bias the exposure and outcome association?
  c. Are the appropriate confounding factors included in the analysis?
5. Intervention (if applicable)
  a. Is the intervention clearly described and transferrable (i.e., could someone else repeat this study with different staff and patients and get similar results)?