# SEARCH STRATEGY

Database: Ovid MEDLINE(R) Search Strategy:
1. exp Hypoglycemia/or hypoglycemia.mp.
2. exp Diabetes Mellitus, Type 2/or type 2 diabetes.mp.
3. 1 and 2
4. limit 3 to (english language and humans)
5. limit 4 to (addresses or bibliography or biography or dictionary or directory or duplicate publication or editorial or interview or introductory journal article or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or portraits or comment or historical article or interview or case reports)
6. 4 not 5
7. limit 6 to “all child (0 to 18 years)”
8. limit 6 to “all adult (19 plus years)”
9. 7 not 8
10. 6 not 9

NOTE: an additional search was performed using the British spelling (hypoglycaemia) as a title/abstract word