# SUMMARY AND DISCUSSION

Observational and biologic plausibility studies suggest an association between hyperglycemia and worsening health outcomes in hospitalized patients. However, trial evidence of the efficacy of tight, compared to less tight, glycemic control strategies using IIT in various inpatient subpopulations is limited. Current evidence does not conclusively support existing guideline recommendations to routinely maintain a blood glucose ≤110 mg/dL in ICU patients, and there is very little data on the health outcome benefits of achieving more moderate blood glucose control (eg – 110 – 180 mg/dL) compared to less strict targets in various inpatient subpopulations.(125)

Single-center evidence from one group of investigators had shown a mortality and morbidity benefit from IIT in subgroups of patients requiring prolonged ICU stays, (16, 22) while our meta-analysis of seven ICU studies showed that achieving normoglycemia using a relatively simple insulin infusion protocol had no effect on short-term mortality but did substantially increase the risk of hypoglycemia.

Several factors may account for the discrepancy in results between the Van den Berghe trials and data from other centers. The aggressive use of parenteral nutrition, especially in the SICU study showing benefit,(16) differs from practice in many centers.(126) Parenteral nutrition has been associated with hypertriglyceridemia, insulin resistance, increased infection rates and mortality, leading to speculation that the observed benefits of intensive insulin in this population actually reflect a reduction in harm from aggressive nutrition practices.(127–131) It is unclear whether the control group mortality rate in this study was higher than expected. The authors of the study have reported mortality rates lower than expected based on the EuroSCORE of the cardiac surgery patients, though a review of EuroSCORE performance characteristics found that scores in the range reported in the trial may underestimate mortality by almost 3 %.(85, 132) On the other hand, a post-hoc analysis using combined data from both the Van den Berghe SICU and MICU studies found a mortality benefit in subgroups receiving the highest and lowest amounts of parenteral glucose.(45)

The exclusive use of arterial blood sampling in the Van den Berghe SICU study also has implications for the applicability of results across diverse ICU settings since very few medical centers use arterial blood sampling to monitor glucose control. Capillary blood sampling is more commonly used and is less dependable in critically ill patients, due to a number of factors including vasopressor therapy, perfusion pressure, pH, and others.(133–135) There is a very low rate of agreement between capillary and whole blood glucose samples, particularly in the hypoglycemic range.(99, 136)

Finally, this SICU study had a relatively low event rate and was stopped early for benefit with less than half the projected number of participants recruited, raising the possibility that the reported treatment effect was larger than the “true” treatment effect.(137) Indeed, the effect size decreased substantially, though remained significant, after the authors adjusted for the repeated interim analyses which had prompted the early recruitment discontinuation.(138)

Three of the trials that failed to show a mortality benefit from achieving normoglycemia in critically ill patients were stopped early due to an excess risk of hypoglycemia in the intervention groups, thus raising the possibility that the lack of observed benefit may actually reflect inadequate power to detect a health benefit.(26, 28, 29) However, the trials did not demonstrate a consistent trend towards benefit and combining these studies in our meta-analysis should increase the power to detect a health benefit if one were present. Furthermore, the inability to implement the insulin infusion protocol in various settings without high rates of hypoglycemia may underscore problems with feasibility and generalizability across institutions. It is unclear whether the high hypoglycemia rates are due to insulin infusion protocol characteristics, staffing characteristics, patient comorbidities, or the very tight glucose target itself. Since the health consequences of insulin-induced hypoglycemia in hospitalized patients are as yet unclear, interventions associated with high rates of hypoglycemia should demonstrate compelling benefit across a variety of institutions before being widely implemented.

The current body of trial evidence in perioperative patients is heterogenous and inconclusive. The most dramatic evidence of health outcome benefits from tight glycemic control in the perioperative setting comes from retrospectively controlled observational studies with methodologic flaws.(14, 15, 88) Well-designed controlled clinical trials in this population would add substantially to our body of knowledge.

Evidence supporting the efficacy of tight glycemic control in myocardial infarction populations is similarly limited and inconsistent. One trial showed a mortality reduction from moderate inpatient and outpatient glucose control in severely hyperglycemic myocardial infarction patients, but this older trial was conducted prior to the widespread use of cholesterol lowering therapies and mechanical revascularization techniques.(13) More recent studies have been negative, but methodologic considerations limit the strength of conclusions drawn from these trials.(46, 47) There is very little fair-good quality empiric data in general surgical or medical ward settings, or in stroke patients.

The ability to achieve glucose targets safely is likely to depend on multiple factors including the titration characteristics of the protocol, patient characteristics, as well as staffing ratios and provider acceptance. A number of mainly single-center observational studies and trials that did not examine health outcomes found relatively low rates of hypoglycemia. Characteristics of these studies suggest there may be several variables responsible for the lower rates of hypoglycemia: modest glucose targets (approximately 100 – 180 mg/dL), an iterative, institution-based protocol development and deployment process, and insulin protocol titration innvovations. There is relatively little information on insulin protocols that have achieved normoglycemic targets with low rates of hypoglycemia.

## Limitations

Our review has several potential limitations. We did not exclude individual trials based on quality rating alone. Thus the strength of our conclusions is inherently limited by the quality variation among included studies. We did make an effort to note particular methodologic limitations, and each study was closely reviewed for overall quality using a rigorously developed approach. The studies included in our quantitative synthesis differed in some important respects: population studied and the attendant differences in event rates (ie – SICU v. MICU), interval of outcome reporting, and glucose monitoring method. The applicability of results from the included studies is limited by a variety of factors: patient characteristics, event rates, concomitant therapy, institution characteristics, and monitoring methodology. Most of these were single-center studies, yet the relative success or failure of an insulin-based intervention is likely to depend, to a significant extent, on systems characteristics which are unique to a given institution or health system. Finally, the included trials relied on glucose measurements from a defined reference time, rather than 24 hour glucose levels achieved, thus potentially obscuring the inherent variability in glucose control through the course of intensive care.(139)

## Future research recommendations

The bulk of efficacy evidence comes from studies in critically ill populations. Even amongst these studies, the patient characteristics, underlying event rates, and risk of hypoglycemia varied substantially. There is almost no empiric data available to guide glucose management practice in non-ICU settings. Future trials should enroll general medical and surgical ward patients.

The current body of evidence has not defined a glucose threshold that should prompt more aggressive intervention in various subpopulations. Given the observed risk of hypoglycemia in patients exposed to insulin therapy designed to normalize blood glucose, and the relatively low hypoglycemia rates in observational studies using less strict targets, the efficacy of higher glucose targets should be examined prospectively in various subpopulations.

As discussed, there are a variety of insulin titration protocols. Those that take into account a patient’s insulin sensitivity and rate of glucose change are theoretically attractive, but future studies should rigorously evaluate these protocols and compare them to simpler protocols.

Individual institutions describing their experience implementing intensive insulin protocols suggest that the increase in nursing workload and fear of hypoglycemia were significant, but surmountable, barriers to implementation.(140, 141) The cost of attaining normal blood glucose in critically ill patients is unclear. Van der Berghe et al found that IIT targeted to normoglycemia was cost-saving using data from their SICU study.(142) Cost analyses using more recent data have not yet been conducted. Since insulin therapy can be resource intensive, future studies should examine the real cost and the opportunity cost of such treatment, as well as patient and staff acceptance across a variety of settings.

Transitions of care (e.g., ICU to ward, hospital to home) are fraught with uncertainty and there is likely a high rate of adverse events during these transitions, including an increased risk of post-discharge hypoglycemia.(143, 144) Studies should examine the safest and most effective ways to adapt insulin management in patients transitioning from one level of care to another.

There is a relative dearth of evidence evaluating the safety and efficacy of non-infusion based insulin protocols. Trials evaluating subcutaneous insulin protocols with moderate glucose targets in the medical ward setting would be of great use to clinicians.

Finally, newer technologies may enhance the safety and efficacy of inpatient glycemic management. Innovations such as continuous blood glucose monitoring systems and computer-based algorithms should be evaluated in various inpatient subpopulations.