# REFERENCES

1 Atkins D, Best D, Briss PA, Eccles M, Falck-Ytter Y, Flottorp S, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
2 Umpierrez GE, Isaacs SD, Bazargan N, You X, Thaler LM, Kitabchi AE. Hyperglycemia: an independent marker of in-hospital mortality in patients with undiagnosed diabetes. Journal of Clinical Endocrinology & Metabolism. 2002;87(3):978-82. [pmid: 11889147].
3 Levetan CS, Passaro M, Jablonski K, Kass M, Ratner RE. Unrecognized diabetes among hospitalized patients. Diabetes Care. 1998;21(2):246-9. [pmid: 9539990].
4 Furnary AP, Gao G, Grunkemeier GL, Wu Y, Zerr KJ, Bookin SO, et al. Continuous insulin infusion reduces mortality in patients with diabetes undergoing coronary artery bypass grafting. Journal of Thoracic & Cardiovascular Surgery. 2003;125(5):1007-21. [pmid: 12771873].
5 Pomposelli JJ, Baxter JK 3rd, Babineau TJ, Pomfret EA, Driscoll DF, Forse RA, et al. Early postoperative glucose control predicts nosocomial infection rate in diabetic patients. Jpen: Journal of Parenteral & Enteral Nutrition. 1998;22(2):77-81. [pmid: 9527963].
6 Bochicchio GV, Salzano L, Joshi M, Bochicchio K, Scalea TM. Admission preoperative glucose is predictive of morbidity and mortality in trauma patients who require immediate operative intervention. American Surgeon. 2005;71(2):171-4. [pmid: 16022019].
7 Capes SE, Hunt D, Malmberg K, Gerstein HC. Stress hyperglycaemia and increased risk of death after myocardial infarction in patients with and without diabetes: a systematic overview. Lancet. 2000;355(9206):773-8. [pmid: 10711923].
8 Capes SE, Hunt D, Malmberg K, Pathak P, Gerstein HC. Stress hyperglycemia and prognosis of stroke in nondiabetic and diabetic patients: a systematic overview. Stroke. 2001;32(10):2426-32. [pmid: 11588337].
9 Rady MY, Johnson DJ, Patel BM, Larson JS, Helmers RA. Influence of individual characteristics on outcome of glycemic control in intensive care unit patients with or without diabetes mellitus. Mayo Clinic Proceedings. 2005;80(12):1558-67. [pmid: 16342648].
10 Krinsley JS, Krinsley JS. Association between hyperglycemia and increased hospital mortality in a heterogeneous population of critically ill patients. Mayo Clinic Proceedings. 2003;78(12):1471-8. [pmid: 14661676].
11 McCowen KC, Malhotra A, Bistrian BR. Stress-induced hyperglycemia. Critical Care Clinics. 2001;17(1):107-24. [pmid: 11219223].
12 Clement S, Braithwaite SS, Magee MF, Ahmann A, Smith EP, Schafer RG, et al. Management of diabetes and hyperglycemia in hospitals. Diabetes Care. 2004;27(2):553-91. [pmid: 14747243].
13 Malmberg K, Ryden L, Efendic S, Herlitz J, Nicol P, Waldenstrom A, et al. Randomized trial of insulin-glucose infusion followed by subcutaneous insulin treatment in diabetic patients with acute myocardial infarction (DIGAMI study): effects on mortality at 1 year. Journal of the American College of Cardiology. 1995;26(1):57-65. [pmid: 7797776].
14 Furnary AP, Cheek DB, Holmes SC, Howell WL, Kelly SP. Achieving tight glycemic control in the operating room: lessons learned from 12 years in the trenches of a paradigm shift in anesthetic care. Seminars in Thoracic & Cardiovascular Surgery. 2006;18(4):339-45. [pmid: 17395031].
15 Zerr KJ, Furnary AP, Grunkemeier GL, Bookin S, Kanhere V, Starr A. Glucose control lowers the risk of wound infection in diabetics after open heart operations. Annals of Thoracic Surgery. 1997;63(2):356-61. [pmid: 9033300].
16 van den Berghe G, Wouters P, Weekers F, Verwaest C, Bruyninckx F, Schetz M, et al. Intensive insulin therapy in the critically ill patients. New England Journal of Medicine. 2001;345(19):1359-67. [pmid: 11794168].
17 Furnary AP, Zerr KJ, Grunkemeier GL, Starr A. Continuous intravenous insulin infusion reduces the incidence of deep sternal wound infection in diabetic patients after cardiac surgical procedures. Annals of Thoracic Surgery. 1999;67(2):352-60. discussion 360–2. [pmid: 10197653].
18 van den Berghe G, Weekers F, Baxter RC, Wouters P, Iranmanesh A, Bouillon R, et al. Five-day pulsatile gonadotropin-releasing hormone administration unveils combined hypothalamic-pituitary-gonadal defects underlying profound hypoandrogenism in men with prolonged critical illness. Journal of Clinical Endocrinology & Metabolism. 2001;86(7):3217-26. [pmid: 11443192].
19 Institute for Health Care Improvement. Establish a glycemic control policy in your ICU. http://www.ihi.org/IHI/Topics/CriticalCare/IntensiveCare/Changes/IndividualChanges/EstablishaGlycemicControlPolicyinYourICU.htm. 2008.
20 Davies RR, Newton RW, McNeill GP, Fisher BM, Kesson CM, Pearson D. Metabolic control in diabetic subjects following myocardial infarction: difficulties in improving blood glucose levels by intravenous insulin infusion. Scottish Medical Journal. 1991;36(3):74-6. [pmid: 1925506].
21 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force. A review of the process. American Journal of Preventive Medicine. 2001;30(3S):21-35. [pmid: 11306229].
22 Van den Berghe G, Wilmer A, Hermans G, Meersseman W, Wouters PJ, Milants I, et al. Intensive insulin therapy in the medical ICU. New England Journal of Medicine. 2006;354(5):449-61. [pmid: 16452557].
23 Farah R, Samokhvalov A, Zviebel F, Makhoul N. Insulin therapy of hyperglycemia in intensive care. Israel Medical Association Journal: Imaj. 2007;9(3):140-2.
24 Grey NJ, Perdrizet GA. Reduction of nosocomial infections in the surgical intensive-care unit by strict glycemic control. Endocrine Practice. 2004;10(Suppl 2):46-52. [pmid: 15251640].
25 Mitchell I, Knight E, Gissane J, Tamhane R, Kolli R, Leditschke IA, et al. A phase II randomised controlled trial of intensive insulin therapy in general intensive care patients. Critical Care & Resuscitation. 2006;8(4):289-93. [pmid: 17227263].
26 Arabi YM, Dabbagh OC, Tamim HM, Al-Shimemeri AA, Memish ZA, Haddad SH, et al. Intensive versus conventional Insulin therapy: a randomized controlled trial in medical and surgical critically ill patients. Accepted for publication.
27 Mackenzie IM, Blunt M, Ingle S, Palmer CR. GLYcaemic Control and Outcome in GENeral Intensive Care: The East Anglian GLYCOGENIC study. Unpublished report.
28 Preiser JC. NIH Glucontrol Study: Comparing the Effects of Two Glucose Control Regimens by Insulin in Intensive Care Unit Patients. http://www.clinicaltrials.gov/ct/gui/show/NCT00107601. Submitted for publication.
29 Brunkhorst FM, Engel C, Bloos F, Meier-Hellmann A, Ragaller M, Weiler N, et al. Intensive Insulin Therapy and Pentastarch Resuscitation in Severe Sepsis. New England Journal of Medicine. 2008;358(2):125-139. [pmid: 18184958].
30 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clinical Trials. 1986;7(3):177-88. [pmid: 3802833].
31 Higgins JPT, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
32 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
33 Finfer S. NICE-SUGAR – A multicentre, open label randomised stratified controlled trial of the effects of blood glucose management on 90-day all-cause mortality in a heterogeneous population of intensive care unit (ICU) patients. http://www.controlled-trials.com/ISRCTN04968275.
34 Iwamoto G. Comparative Trial Between 3 Types of Insulin Infusion Protocols clinicaltrials.gov. accessed 6/09/08. Study ID:NCT00582309; in progress.
35 Umpierrez GE. Trial Between a Computer-Guided Insulin Infusion Protocol Versus a Standard Insulin Infusion Algorithm in Medical ICU. clinicaltrials.gov. accessed 6/09/08. Study ID:NCT00394524; in progress.
36 Lacherade JC. Impact of 2 Blood Glucose Levels on Hospital Mortality in Patients Admitted in ICU (INSUREA). ClinicalTrials.gov. Study ID: NCT00591071; in progress.
37 De La Rosa GD. Tight Glycemic Control in Critical Care Patients. ClinicalTrials.gov. Study ID: NCT00096421; completed.
38 Azevedo JR, de Araujo LO, Azevedo RP, Silva WS, Cruz FL. Intensive insulin therapy versus glycemic control in critically ill patients: a prospective controlled trial. Critical Care. 2007;11.
39 Ingels C, Debaveye Y, Milants I, Buelens E, Peeraer A, Devriendt Y, et al. Strict blood glucose control with insulin during intensive care after cardiac surgery: impact on 4-years survival, dependency on medical care, and quality-of-life. European Heart Journal. 2006;27(22):2716-24. [pmid: 16608860].
40 Bistrian BR, McCowen KC. Nutritional and metabolic support in the adult intensive care unit: key controversies. Critical Care Medicine. 2006;34(5):1525-31. [pmid: 16557154].
41 Heyland DK, Dhaliwal R, Drover JW, Gramlich L, Dodek P. Canadian Critical Care Clinical Practice Guidelines C. Canadian clinical practice guidelines for nutrition support in mechanically ventilated, critically ill adult patients. Jpen: Journal of Parenteral & Enteral Nutrition. 2003;27(5):355-73. [pmid: 12971736].
42 Kanji S, Buffie J, Hutton B, Bunting PS, Singh A, McDonald K, et al. Reliability of point-of-care testing for glucose measurement in critically ill adults. Critical Care Medicine. 2005;33(12):2778-85. [pmid: 16352960].
43 Wiener RSMDMPH, Wiener DCMD, Larson RJMDMPH. Benefits and Risks of Tight Glucose Control in Critically Ill Adults: A Meta-analysis. JAMA. 2008;300(8):933-944. [pmid: 18728267].
44 Finfer S. Personal Communication.
45 Van den Berghe G, Wilmer A, Milants I, Wouters PJ, Bouckaert B, Bruyninckx F, et al. Intensive insulin therapy in mixed medical/surgical intensive care units: benefit versus harm. Diabetes. 2006;55(11):3151-9. [pmid: 17065355].
46 Cheung NW, Wong VW, McLean M. The Hyperglycemia: Intensive Insulin Infusion in Infarction (HI-5) study: a randomized controlled trial of insulin infusion therapy for myocardial infarction. Diabetes Care. 2006;29(4):765-70. [pmid: 16567812].
47 Malmberg K, Ryden L, Wedel H, Birkeland K, Bootsma A, Dickstein K, et al. Intense metabolic control by means of insulin in patients with diabetes mellitus and acute myocardial infarction (DIGAMI 2): effects on mortality and morbidity. European Heart Journal. 2005;26(7):650-61. [pmid: 15728645].
48 Oksanen T, Skrifvars MB, Varpula T, Kuitunen A, Pettila V, Nurmi J, et al. Strict versus moderate glucose control after resuscitation from ventricular fibrillation. Intensive Care Medicine. 2007;33(12):2093-100. [pmid: 17928994].
49 van der Horst ICC, Zijlstra F, van’t Hof AWJ, Doggen CJM, de Boer M-J, Suryapranata H, et al. Glucose-insulin-potassium infusion inpatients treated with primary angioplasty for acute myocardial infarction: the glucose-insulin-potassium study: a randomized trial. Journal of the American College of Cardiology. 2003;42(5):784-91. [pmid: 12957421].
50 Rasoul S, Ottervanger JP, Timmer JR, Svilaas T, Henriques JPS, Dambrink J-HE, et al. One year outcomes after glucose-insulin-potassium in ST elevation myocardial infarction. The Glucose-insulin-potassium study II. International Journal of Cardiology. 2007;122(1):52-5. [pmid: 17223212].
51 Mellbin LG, Malmberg K, Norhammar A, Wedel H, Ryden L, Investigators D. The impact of glucose lowering treatment on long-term prognosis in patients with type 2 diabetes and myocardial infarction: a report from the DIGAMI 2 trial. European Heart Journal. 2008;29(2):166-76. [pmid: 18156614].
52 Timmer JR, Svilaas T, Ottervanger JP, Henriques JPS, Dambrink J-HE, van den Broek SAJ, et al. Glucose-insulin-potassium infusion in patients with acute myocardial infarction without signs of heart failure: the Glucose-Insulin-Potassium Study (GIPS)-II. Journal of the American College of Cardiology. 2006;47(8):1730-1. [pmid: 16631017].
53 Mehta SR, Yusuf S, Diaz R, Zhu J, Pais P, Xavier D, et al. Effect of glucose-insulin-potassium infusion on mortality in patients with acute ST-segment elevation myocardial infarction: the CREATE-ECLA randomized controlled trial. JAMA. 2005;293(4):437-46. [pmid: 15671428].
54 Yusuf S, Mehta SR, Diaz R, Paolasso E, Pais P, Xavier D, et al. Challenges in the conduct of large simple trials of important generic questions in resource-poor settings: the CREATE and ECLA trial program evaluating GIK (glucose, insulin and potassium) and low-molecular-weight heparin in acute myocardial infarction. American Heart Journal. 2004;148(6):1068-78. [pmid: 15632895].
55 Diaz R, Goyal A, Mehta SR, Afzal R, Xavier D, Pais P, et al. Glucose-insulin-potassium therapy in patients with ST-segment elevation myocardial infarction. JAMA. 2007;298(20):2399-405. [pmid: 18042917].
56 Pache J, Kastrati A, Mehilli J, Bollwein H, Ndrepepa G, Schuhlen H, et al. A randomized evaluation of the effects of glucose-insulin-potassium infusion on myocardial salvage in patients with acute myocardial infarction treated with reperfusion therapy. American Heart Journal. 2004;148(1):e3. [pmid: 15215812].
57 Krljanac G, Vasiljevi Z, Radovanovi M, Stankovi G, Mili N, Stefanovi B, et al. Effects of glucose-insulin-potassium infusion on ST-elevation myocardial infarction in patients treated with thrombolytic therapy. American Journal of Cardiology. 2005;96(8):1053-8. [pmid: 16214437].
58 Turel B, Gemici K, Baran I, Yeilbursa D, Gullulu S, Aydinlar A, et al. Effects of glucose-insulin-potassium solution added to reperfusion treatment in acute myocardial infarction. Anadolu Kardiyoloji Dergisi. 2005;5(2):90-4. [pmid: 15939681].
59 Ceremuzyski L, Budaj A, Czepiel A, Burzykowski T, Achremczyk P, Smielak-Korombel W, et al. Low-dose glucose-insulin-potassium is ineffective in acute myocardial infarction: results of a randomized multicenter Pol-GIK trial. Cardiovascular Drugs & Therapy. 1999;13(3):191-200. [pmid: 10439881].
60 Pittas AG, Siegel RD, Lau J. Insulin therapy and in-hospital mortality in critically ill patients: systematic review and meta-analysis of randomized controlled trials. Jpen: Journal of Parenteral & Enteral Nutrition. 2006;30(2):164-72. [pmid: 16517961].
61 Gray CS, Hildreth AJ, Sandercock PA, O’Connell JE, Johnston DE, Cartlidge NEF, et al. Glucose-potassium-insulin infusions in the management of post-stroke hyperglycaemia: the UK Glucose Insulin in Stroke Trial (GIST-UK). Lancet Neurology. 2007;6(5):397-406. [pmid: 17434094].
62 Bilotta F, Spinelli A, Giovannini F, Doronzio A, Delfini R, Rosa G. The effect of intensive insulin therapy on infection rate, vasospasm, neurologic outcome, and mortality in neurointensive care unit after intracranial aneurysm clipping in patients with acute subarachnoid hemorrhage: a randomized prospective pilot trial. Journal of Neurosurgical Anesthesiology. 2007;19(3):156-60. [pmid: 17592345].
63 Azevedo JRAd, Lima ERM, Cossetti RJD, Azevedo RPd. Intensive insulin therapy versus conventional glycemic control in patients with acute neurological injury: a prospective controlled trial. Arquivos de Neuro-Psiquiatria. 2007;65(3B):733-8. [pmid: 17952272].
64 Li J-Y, Sun S, Wu S-J. Continuous insulin infusion improves postoperative glucose control in patients with diabetes mellitus undergoing coronary artery bypass surgery. Texas Heart Institute Journal. 2006;33(4):445-51. [pmid: 17215967].
65 Butterworth J, Wagenknecht LE, Legault C, Zaccaro DJ, Kon ND, Hammon JW Jr, et al. Attempted control of hyperglycemia during cardiopulmonary bypass fails to improve neurologic or neurobehavioral outcomes in patients without diabetes mellitus undergoing coronary artery bypass grafting. Journal of Thoracic & Cardiovascular Surgery. 2005;130(5):1319. [pmid: 16256784].
66 Gandhi GY, Nuttall GA, Abel MD, Mullany CJ, Schaff HV, O’Brien PC, et al. Intensive intraoperative insulin therapy versus conventional glucose management during cardiac surgery: a randomized trial. Annals of Internal Medicine. 2007;146(4):233-43. [pmid: 17310047].
67 Lazar HL, Chipkin SR, Fitzgerald CA, Bao Y, Cabral H, Apstein CS. Tight glycemic control in diabetic coronary artery bypass graft patients improves perioperative outcomes and decreases recurrent ischemic events. Circulation. 2004;109(12):1497-502. [pmid: 15006999].
68 Smith A, Grattan A, Harper M, Royston D, Riedel BJCJ. Coronary revascularization: a procedure in transition from on-pump to off-pump? The role of glucose-insulin-potassium revisited in a randomized, placebo-controlled study. Journal of Cardiothoracic & Vascular Anesthesia. 2002;16(4):413-20. [pmid: 12154417].
69 Gandhi GY, Murad MH, Flynn DN, Erwin PJ, Cavalcante AB, Bay Nielsen H, et al. Effect of perioperative insulin infusion on surgical morbidity and mortality: systematic review and meta-analysis of randomized trials. Mayo Clinic Proceedings. 2008;83(4):418-30. [pmid: 18380987].
70 Boldt J, Knothe C, Zickmann B, Dunnes S, Dapper F, Hempelmann G. Influence of different glucose-insulin-potassium regimes on glucose homeostasis and hormonal response in cardiac surgery patients. Anesthesia & Analgesia. 1993;76(2):233-8. [pmid: 8424497].
71 Brodin LA, Dahlgren G, Ekestrom S, Settergren G, Ohqvist G. Influence of glucose-insulin-potassium on left ventricular function during coronary artery bypass grafting. Scandinavian Journal of Thoracic & Cardiovascular Surgery. 1993;27(1):27-34. [pmid: 8493493].
72 Koskenkari JK, Kaukoranta PK, Kiviluoma KT, Raatikainen MJP, Ohtonen PP, Ala-Kokko TI. Metabolic and hemodynamic effects of high-dose insulin treatment in aortic valve and coronary surgery. Annals of Thoracic Surgery. 2005;80(2):511-7. [pmid: 16039195].
73 Lindholm L, Bengtsson A, Hansdottir V, Westerlind A, Jeppsson A. Insulin (GIK) improves central mixed and hepatic venous oxygenation in clinical cardiac surgery. Scandinavian Cardiovascular Journal. 2001;35(5):347-52. [pmid: 11771827].
74 Lolley DM, Ray JF 3rd, Myers WO, Sheldon G, Sautter RD. Reduction of intraoperative myocardial infarction by means of exogenous anaerobic substrate enhancement: prospective randomized study. Annals of Thoracic Surgery. 1978;26(6):515-24. [pmid: 313765].
75 Oldfield GS, Commerford PJ, Opie LH. Effects of preoperative glucose-insulin-potassium on myocardial glycogen levels and on complications of mitral valve replacement. Journal of Thoracic & Cardiovascular Surgery. 1986;91(6):874-8. [pmid: 3520160].
76 Rao V, Borger MA, Weisel RD, Ivanov J, Christakis GT, Cohen G, et al. Insulin cardioplegia for elective coronary bypass surgery. Journal of Thoracic & Cardiovascular Surgery. 2000;119(6):1176-84. [pmid: 10838535].
77 Rassias AJ, Marrin CA, Arruda J, Whalen PK, Beach M, Yeager MP. Insulin infusion improves neutrophil function in diabetic cardiac surgery patients. Anesthesia & Analgesia. 1999;88(5):1011-6. [pmid: 10320160].
78 Rassias AJ, Givan AL, Marrin CA, Whalen K, Pahl J, Yeager MP, et al. Insulin increases neutrophil count and phagocytic capacity after cardiac surgery. Anesthesia & Analgesia. 2002;94(5):1113-9. [pmid: 11973171].
79 Raucoules-Aime M, Lugrin D, Boussofara M, Gastaud P, Dolisi C, Grimaud D. Intraoperative glycaemic control in non-insulin-dependent and insulin-dependent diabetes. British Journal of Anaesthesia. 1994;73(4):443-9. [pmid: 7999482].
80 Raucoules-Aime M, Ichai C, Roussel LJ, Romagnan MJ, Gastaud P, Dolisi C, et al. Comparison of two methods of i.v. insulin administration in the diabetic patient during the perioperative period. British Journal of Anaesthesia. 1994;72(1):5-10. [pmid: 8110550].
81 Wallin M, Barr G, oWall A, Lindahl SGe, Brismar K. The influence of glucose-insulin-potassium (GIK) on the GH/IGF-1/IGFBP-1 axis during elective coronary artery bypass surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2003;17(4):470-7. [pmid: 12968235].
82 Visser L, Zuurbier CJ, Hoek FJ, Opmeer BC, de Jonge E, de Mol BAJM, et al. Glucose, insulin and potassium applied as perioperative hyperinsulinaemic normoglycaemic clamp: effects on inflammatory response during coronary artery surgery. British Journal of Anaesthesia. 2005;95(4):448-57. [pmid: 16100235].
83 Wistbacka JO, Lepojarvi MV, Karlqvist KE, Koistinen J, Kaukoranta PK, Nissinen J, et al. Amino acid-enriched glucose-insulin-potassium infusion improves hemodynamic function after coronary bypass surgery. A double-blind study in patients with unstable angina and/or compromised left ventricular function. Infusionstherapie und Transfusionsmedizin. 1995;22(2):82-90. [pmid: 7787408].
84 Valarini R, Sousa MF, Kalil R, Abumrad NN, Riella MC. Anabolic effects of insulin and amino acids in promoting nitrogen accretion in postoperative patients. Jpen: Journal of Parenteral & Enteral Nutrition. 1994;18(3):214-8. [pmid: 8064995].
85 Gogbashian A, Sedrakyan A, Treasure T. EuroSCORE: a systematic review of international performance. European Journal of Cardio-Thoracic Surgery. 2004;25(5):695-700. [pmid: 15082269].
86 Nilsson J, Algotsson L, Hoglund P, Luhrs C, Brandt J. Early mortality in coronary bypass surgery: the EuroSCORE versus The Society of Thoracic Surgeons risk algorithm. Annals of Thoracic Surgery. 2004;77(4):1235-9. discussion 1239–40. [pmid: 15063242].
87 Toumpoulis IK, Anagnostopoulos CE, Toumpoulis SK, DeRose JJ Jr, Swistel DG. EuroSCORE predicts long-term mortality after heart valve surgery. Annals of Thoracic Surgery. 2005;79(6):1902-8. [pmid: 15919281].
88 D’Alessandro C, Leprince P, Golmard JL, Ouattara A, Aubert S, Pavie A, et al. Strict glycemic control reduces EuroSCORE expected mortality in diabetic patients undergoing myocardial revascularization. Journal of Thoracic & Cardiovascular Surgery. 2007;134(1):29-37. [pmid: 17599483].
89 Krinsley JS. Glycemic control, diabetic status, and mortality in a heterogeneous population of critically ill patients before and during the era of intensive glycemic management: six and one-half years experience at a university-affiliated community hospital. Seminars in Thoracic & Cardiovascular Surgery. 2006;18(4):317-25. [pmid: 17395028].
90 Ioannidis JP, Haidich AB, Pappa M, Pantazis N, Kokori SI, Tektonidou MG, et al. Comparison of evidence of treatment effects in randomized and nonrandomized studies. JAMA. 2001;286(7):821-30. [pmid: 11497536].
91 Hartl WH, Wolf H, Schneider CP, Kuchenhoff H, Jauch K-W. Secular trends in mortality associated with new therapeutic strategies in surgical critical illness. American Journal of Surgery. 2007;194(4):535-41. [pmid: 17826075].
92 Hedrick TL, Heckman JA, Smith RL, Sawyer RG, Friel CM, Foley EF. Efficacy of protocol implementation on incidence of wound infection in colorectal operations. Journal of the American College of Surgeons. 2007;205(3):432-8. [pmid: 17765159].
93 Haycock C, Laser C, Keuth J, Montefour K, Wilson M, Austin K, et al. Implementing evidence-based practice findings to decrease postoperative sternal wound infections following open heart surgery. Journal of Cardiovascular Nursing. 2005;20(5):299-305. [pmid: 16141774].
94 Fischer KF, Lees JA, Newman JH. Hypoglycemia in hospitalized patients. Causes and outcomes. New England Journal of Medicine. 1986;315(20):1245-50. [pmid: 3534567].
95 Shilo S, Berezovsky S, Friedlander Y, Sonnenblick M. Hypoglycemia in hospitalized nondiabetic older patients. Journal of the American Geriatrics Society. 1998;46(8):978-82. [pmid: 9706886].
96 Vriesendorp TM, van Santen S, DeVries JH, de Jonge E, Rosendaal FR, Schultz MJ, et al. Predisposing factors for hypoglycemia in the intensive care unit. Critical Care Medicine. 2006;34(1):96-101. [pmid: 16374162].
97 Krinsley J. Glycemic control in critically ill patients: Leuven and beyond. Chest. 2007;132(1):1-2. [pmid: 17625075].
98 Chant C, Wilson G, Friedrich JO. Validation of an insulin infusion nomogram for intensive glucose control in critically ill patients. Pharmacotherapy. 2005;25(3):352-9. [pmid: 15843282].
99 Kanji S, Singh A, Tierney M, Meggison H, McIntyre L, Hebert PC. Standardization of intravenous insulin therapy improves the efficiency and safety of blood glucose control in critically ill adults. Intensive Care Medicine. 2004;30(5):804-10. [pmid: 15127193].
100 Plank J, Blaha J, Cordingley J, Wilinska ME, Chassin LJ, Morgan C, et al. Multicentric, randomized, controlled trial to evaluate blood glucose control by the model predictive control algorithm versus routine glucose management protocols in intensive care unit patients. Diabetes Care. 2006;29(2):271-6. [pmid: 16443872].
101 Toft P, Jorgensen HS, Toennesen E, Christiansen C. Intensive insulin therapy to non-cardiac ICU patients: a prospective study. European Journal of Anaesthesiology. 2006;23(8):705-9. [pmid: 16805937].
102 Mechanick JI, Handelsman Y, Bloomgarden ZT. Hypoglycemia in the intensive care unit. Current Opinion in Clinical Nutrition & Metabolic Care. 2007;10(2):193-6. [pmid: 17285009].
103 Mackenzie I, Ingle S, Zaidi S, Buczaski S. Tight glycaemic control: a survey of intensive care practice in large English hospitals. Intensive Care Medicine. 2005;31(8):1136. [pmid: 16052274].
104 Desouza C, Salazar H, Cheong B, Murgo J, Fonseca V. Association of hypoglycemia and cardiac ischemia: a study based on continuous monitoring. Diabetes Care. 2003;26(5):1485-9. [pmid: 12716809].
105 Lindstrom T, Jorfeldt L, Tegler L, Arnqvist HJ. Hypoglycaemia and cardiac arrhythmias in patients with type 2 diabetes mellitus. Diabetic Medicine. 1992;9(6):536-41. [pmid: 1643801].
106 Spyer G, Hattersley AT, MacDonald IA, Amiel S, MacLeod KM. Hypoglycaemic counter-regulation at normal blood glucose concentrations in patients with well controlled type-2 diabetes. Lancet. 2000;356(9246):1970-4. [pmid: 11130525].
107 van der Horst ICC, De Luca G, Ottervanger JP, de Boer M-J, Hoorntje JCA, Suryapranata H, et al. ST-segment elevation resolution and outcome in patients treated with primary angioplasty and glucose-insulin-potassium infusion. American Heart Journal. 2005;149(6):1135.
108 Balkin M, Mascioli C, Smith V, Alnachawati H, Mehrishi S, Saydain G, et al. Achieving durable glucose control in the intensive care unit without hypoglycaemia: a new practical IV insulin protocol. Diabetes/Metabolism Research Reviews. 2007;23(1):49-55.
109 DeSantis AJ, Schmeltz LR, Schmidt K, O’Shea-Mahler E, Rhee C, Wells A, et al. Inpatient management of hyperglycemia: the Northwestern experience. Endocrine Practice. 2006;12(5):491-505. [pmid: 17002924].
110 Goldberg PA, Sakharova OV, Barrett PW, Falko LN, Roussel MG, Bak L, et al. Improving glycemic control in the cardiothoracic intensive care unit: clinical experience in two hospital settings. Journal of Cardiothoracic & Vascular Anesthesia. 2004;18(6):690-7. [pmid: 15650975].
111 Cochran A, Davis L, Morris SE, Saffle JR. Safety and efficacy of an intensive insulin protocol in a burn-trauma intensive care unit. Journal of Burn Care & Research. 2008;29(1):187-91. [pmid: 18182920].
112 Braithwaite SS, Edkins R, Macgregor KL, Sredzienski ES, Houston M, Zarzaur B, et al. Performance of a dose-defining insulin infusion protocol among trauma service intensive care unit admissions. Diabetes Technology & Therapeutics. 2006;8(4):476-88. [pmid: 16939372].
113 Dortch MJ, Mowery NT, Ozdas A, Dossett L, Cao H, Collier B, et al. A computerized insulin infusion titration protocol improves glucose control with less hypoglycemia compared to a manual titration protocol in a trauma intensive care unit. Jpen: Journal of Parenteral & Enteral Nutrition. 2008;32(1):18-27. [pmid: 18165443].
114 Juneja R, Roudebush C, Kumar N, Macy A, Golas A, Wall D, et al. Utilization of a computerized intravenous insulin infusion program to control blood glucose in the intensive care unit. Diabetes Technology & Therapeutics. 2007;9(3):232-40. [pmid: 17561793].
115 Zimmerman CR, Mlynarek ME, Jordan JA, Rajda CA, Horst HM. An insulin infusion protocol in critically ill cardiothoracic surgery patients. Annals of Pharmacotherapy. 2004;38(7–8):1123-9. [pmid: 15150382].
116 Nazer LH, Chow SL, Moghissi ES. Insulin infusion protocols for critically ill patients: a highlight of differences and similarities. Endocrine Practice. 2007;13(2):137-46. [pmid: 17490927].
117 Meijering S, Corstjens AM, Tulleken JE, Meertens JHJM, Zijlstra JG, Ligtenberg JJM. Towards a feasible algorithm for tight glycaemic control in critically ill patients: a systematic review of the literature. Critical Care (London, England). 2006;10(1):R19.
118 Wilson M, Weinreb J, Hoo GW, Wilson M, Weinreb J, Hoo GWS. Intensive insulin therapy in critical care: a review of 12 protocols. Diabetes Care. 2007;30(4):1005-11. [pmid: 17213376].
119 Elinav H, Wolf Z, Szalat A, Bdolah-Abram T, Glaser B, Raz I, et al. In-hospital treatment of hyperglycemia: effects of intensified subcutaneous insulin treatment. Current Medical Research & Opinion. 2007;23(4):757-65. [pmid: 17407632].
120 Miriam A, Korula G. A simple glucose insulin regimen for perioperative blood glucose control: the Vellore regimen. Anesthesia & Analgesia. 2004;99(2):598-602. [pmid: 15271748].
121 Metchick LN, Petit WA Jr, Inzucchi SE. Department of Medicine UoCSoMFC, Joslin Diabetes Center NBC, Section of Endocrinology DoMYUSoMNHC. Inpatient management of diabetes mellitus. American Journal of Medicine. 2002;113(4):317-23. [pmid: 12361818].
122 Umpierrez GE, Smiley D, Zisman A, Prieto LM, Palacio A, Ceron M, et al. Randomized study of basal-bolus insulin therapy in the inpatient management of patients with type 2 diabetes (RABBIT 2 trial). Diabetes Care. 2007;30(9):2181-6. [pmid: 17513708].
123 Datta S, Qaadir A, Villanueva G, Baldwin D. Once-daily insulin glargine versus 6-hour sliding scale regular insulin for control of hyperglycemia after a bariatric surgical procedure: a randomized clinical trial. Endocrine Practice. 2007;13(3):225-31. [pmid: 17599852].
124 Dickerson LM, Ye X, Sack JL, Hueston WJ. Glycemic control in medical inpatients with type 2 diabetes mellitus receiving sliding scale insulin regimens versus routine diabetes medications: a multicenter randomized controlled trial. Annals of Family Medicine. 2003;1(1):29-35. [pmid: 15043177].
125 Garber AJ, Moghissi ES, Bransome ED Jr, Clark NG, Clement S, Cobin RH, et al. American College of Endocrinology position statement on inpatient diabetes and metabolic control. Endocrine Practice. 2004;10(1):77-82. [pmid: 15251626].
126 Needham PJ, Burton AB, Jayne DG. Artifical nutrition in UK intensive care units: a review of current practice. Proceedings of the Nutrition Society. 2008;67(OCE):E152.
127 Lewis KS, Kane-Gill SL, Bobek MB, Dasta JF. Intensive insulin therapy for critically ill patients. Annals of Pharmacotherapy. 2004;38(7–8):1243-51. [pmid: 15187219].
128 O’Keefe SJD, Lee RB, Anderson FP, Gennings C, Abou-Assi S, Clore J, et al. Physiological effects of enteral and parenteral feeding on pancreaticobiliary secretion in humans. American Journal of Physiology - Gastrointestinal & Liver Physiology. 2003;284(1):G27-36. [pmid: 12488233].
129 Braunschweig CL, Levy P, Sheean PM, Wang X. Enteral compared with parenteral nutrition: a meta-analysis. American Journal of Clinical Nutrition. 2001;74(4):534-42. [pmid: 11566654].
130 Klein CJ, Stanek GS, Wiles CE 3rd. Overfeeding macronutrients to critically ill adults: metabolic complications. Journal of the American Dietetic Association. 1998;98(7):795-806. [pmid: 9664922].
131 Brunkhorst F, Reinhart K, Engel C. Insulin and Pentastarch for Severe Sepsis. New England Journal of Medicine. 2008;358(19):2074-2075.
132 Van den Berghe G, Wilmer A, Bouillon R, Van den Berghe G, Wilmer A, Bouillon R. Insulin and pentastarch for severe sepsis. New England Journal of Medicine. 2008;358(19):2073. author reply 2074–5. [pmid: 18467979].
133 Atkin SH, Dasmahapatra A, Jaker MA, Chorost MI, Reddy S. Fingerstick glucose determination in shock. Annals of Internal Medicine. 1991;114(12):1020-4. [pmid: 2029097].
134 Critchell CD, Savarese V, Callahan A, Aboud C, Jabbour S, Marik P. Accuracy of bedside capillary blood glucose measurements in critically ill patients. Intensive Care Medicine. 2007;33(12):2079-84. [pmid: 17763842].
135 Tanvetyanon T, Walkenstein MD, Marra A. Inaccurate glucose determination by fingerstick in a patient with peripheral arterial disease. Annals of Internal Medicine. 2002;137(9):W1. [pmid: 12416976].
136 Desachy A, Vuagnat AC, Ghazali AD, Baudin OT, Longuet OH, Calvat SN, et al. Accuracy of bedside glucometry in critically ill patients: influence of clinical characteristics and perfusion index. Mayo Clinic Proceedings. 2008;83(4):400-5. [pmid: 18380985].
137 Montori VM, Devereaux PJ, Adhikari NKJ, Burns KEA, Eggert CH, Briel M, et al. Randomized Trials Stopped Early for Benefit: A Systematic Review. JAMA. 2005;294(17):2203-2209. [pmid: 16264162].
138 Lan KKG, DeMets DL. Discrete sequential boundaries for clinical trials. Biometrika. 1983;70(3):659-663.
139 Finney SJ, Zekveld C, Elia A, Evans TW, Finney SJ, Zekveld C, et al. Glucose control and mortality in critically ill patients. JAMA. 2003;290(15):2041-7. [pmid: 14559958].
140 Goldberg PA, Inzucchi SE. Selling root canals: lessons learned from implementing a hospital insulin infusion protocol. Diabetes Spectrum. 2005;18(1):28-33.
141 Rea RS, Donihi AC, Bobeck M, Herout P, McKaveney TP, Kane-Gill SL, et al. Implementing an intravenous insulin infusion protocol in the intensive care unit. American Journal of Health-System Pharmacy. 2007;64(4):385-95. [pmid: 17299178].
142 Van den Berghe G, Wouters PJ, Kesteloot K, Hilleman DE. Analysis of healthcare resource utilization with intensive insulin therapy in critically ill patients. Critical Care Medicine. 2006;34(3):612-6. [pmid: 16521256].
143 Forster AJ, Murff HJ, Peterson JF, Gandhi TK, Bates DW. The incidence and severity of adverse events affecting patients after discharge from the hospital. Annals of Internal Medicine. 2003;138(3):161-7. [pmid: 12558354].
144 Shorr RI, Ray WA, Daugherty JR, Griffin MR. Incidence and risk factors for serious hypoglycemia in older persons using insulin or sulfonylureas. Archives of Internal Medicine. 1997;157(15):1681-6. [pmid: 9250229].