# METHODS

## Topic Development

The review was commissioned by the Department of Veterans Affairs’ Evidence-based Synthesis Program. We conferred with VA and non-VA experts to select the patients and subgroups, interventions, outcomes, and setting addressed in the review.

The objectives of this review are to address the following questions:

1. Does the use of intensive insulin therapy (IIT) to achieve tight glycemic control compared to less tight glycemic control improve final health outcomes in the following patients?
  - patients in the surgical intensive care unit
  - patients in the medical intensive care unit
  - patients in the perioperative setting
  - acute myocardial infarction patients
  - acute stroke patients
  - general surgical ward patients
  - general medicine ward patients
2. What are the harms of strict glycemic control in the above subpopulations?
3. What are the most effective and safest means of lowering blood glucose in the above subpopulations?

Figure 1 illustrates the analytic framework that guided our review and synthesis.

Figure 1 Analytic Framework

## Search Strategy

We conducted a search in Medline and the Cochrane database of systematic reviews of literature published from 1950 through May 2008. Appendix A provides the search strategy in detail. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting experts. We also searched for information about unpublished studies on clinicaltrials.gov. All citations were imported into an electronic database (EndNote X1).

## Study Selection

Three reviewers assessed for relevance the abstracts of citations identified from literatures searches. Full-text articles of potentially relevant abstracts were retrieved for further review. Each article retrieved was reviewed using the eligibility criteria shown in Appendix B.

Eligible articles had English-language abstracts and provided primary data relevant to the key questions. Eligibility criteria varied depending on the question of interest, as described below.

To evaluate the efficacy of intensive insulin therapy (IIT) in hospitalized patients, we considered prospective, controlled clinical trials of insulin-based protocols targeted to strict glycemic targets compared to those targeted to less strict glycemic targets. We also considered clinical trials of fixed-dose insulin-based treatment regimens in myocardial infarction patients. The studies had to report at least one prespecified final health outcome (Appendix B). Unpublished studies were included if the authors could provide enough information about the methodology and results to fully evaluate the study’s quality. We excluded insulin-based studies conducted in myocardial infarction patients prior to widespread availability of thrombolytics (i.e., enrolling patients prior to 1990).(20) We categorized perioperative trials as those in which IIT was begun pre-, intra-, or immediately post-operatively, and was continued for less than 24 hours postoperatively. We considered patients in neurologic, neurosurgical, and coronary intensive care units separately from patients in general medical and surgical ICUs. Though observational studies using historic control groups were initially excluded from our review, after consultation with experts we decided to include a discussion and critique of frequently cited observational studies.

To assess the risk of hypoglycemia associated with IIT, we included controlled trials and uncontrolled series that reported rates of hypoglycemia in ICU patients treated with IIT, even if they did not report health outcomes. In order to avoid studies with substantial selection bias, we included only interventional prospective cohort studies in which patients were consecutively enrolled and in which there was minimal loss to follow-up. Because tight glycemic control strategies require some personnel training and institutional acceptance, we included only studies in which the intervention was evaluated over a prolonged period of time (defined as 6 months for the purposes of this review) as we felt these studies were most likely to provide externally valid results.

To assess the effectiveness of specific inpatient blood glucose control strategies in lowering blood glucose, we evaluated fair to good quality systematic reviews of insulin infusion protocols. Because of the relative dearth of information guiding insulin management in general medical or surgical ward patients, we also included primary data from controlled clinical trials evaluating subcutaneous insulin management strategies in general medical or surgical ward patients (e.g., those that compared sliding scale insulin to scheduled insulin).

## Data abstraction

From each study we abstracted the following: study design, objectives, setting, population characteristics (including sex, age, baseline morbidity), subject eligibility and exclusion criteria, number of subjects, years of enrollment, duration of follow-up, the study and comparator interventions, the method used to monitor blood glucose, the target range for blood glucose control, the outcomes measured, the analytic method used, the variables adjusted in the analysis, the results of the study and the mean blood glucose achieved in each group, information on concomitant therapy/nutrition, the occurrence of hypoglycemia in each group, and any other adverse events.

## Rating the body of evidence

We assessed the overall quality of evidence for outcomes using a method developed by the Grade Working Group.(1) The Grade method considers the consistency, coherence, and applicability of a body of evidence, as well as the internal validity of individual studies to classify the grade of evidence across outcomes as follows:

High = Further research is very unlikely to change our confidence on the estimate of effect.

Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.

Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Very Low = Any estimate of effect is very uncertain.

The quality of each study was rated as good, fair, or poor based on the following criteria: the comparability of treatment groups; the adequacy of randomization; whether treatment allocation was concealed; whether eligibility criteria were specified; the use of blinding among patients, care providers, and outcome assessors; whether the analysis was intention-to-treat, or conducted with post-randomization exclusions, or with extensive or differential loss to follow-up; clearly defined interventions and reliable outcome measurement (Appendix C).(21) When reviewers disagreed, consensus was reached through discussion with all authors.

## Data synthesis

Because all ICU trials except one (22) were either small (n < 100) (23–25) or did not reach recruitment goals (16, 26–29), we performed a meta-analysis of trials conducted in critical care settings to estimate with greater power the effects of achieving normoglycemia using IIT on short-term mortality and hypoglycemia. The clinical heterogeneity of insulin interventions, glucose targets, and population characteristics precluded quantitative analysis within the perioperative, myocardial infarction, and stroke subgroups. We abstracted the number of events and total subjects from each treatment arm, and obtained a pooled estimate of relative risk (RR) using a random effects model.(30) Trials reporting hospital or 28-day mortality were included in the short-term mortality analysis. We performed sensitivity analyses to assess the effects of short-term mortality definition (i.e. hospital or 28 day mortality), as well as the effects of excluding trials using higher intervention glucose targets.

Statistical heterogeneity was assessed by Cochran’s Q test and I^2^ statistic.(31) Because of the small number of trials that could be combined, we did not perform assessments for publication bias.(32) All analyses were performed using Stata 10.0 (StataCorp, College Station, TX, 2007).

## Peer review

A draft version of this report was sent to the technical advisory panel and additional peer reviewers. Their comments and our responses are shown in Appendix D.