# CONCLUSIONS

The use of intensive insulin therapy to achieve normoglycemia in critically ill patients does not clearly result in health outcome benefits and is associated with high rates of hypoglycemia. More moderate blood glucose control to targets above the normoglycemic range can likely be safely achieved, though the health outcome benefit of this practice has not been well studied. Tables 6 and 7 summarize the findings of this systematic review for each key question.

Table 6 Summary of Systematic Evidence Review, Key Question 1

Does strict glycemic control compared to less strict glycemic control improve final health outcomes in the following patients?

Patient subgroup | Type of Evidence | Quality (GRADE) of Evidence | Comments | Net effect^*^
Acute myocardial infarction patients | 2 systematic reviews; 10 RCTs | High = Further research is unlikely to change our confidence on the estimate of effect. | We found good quality evidence that insulin used as part of a fixed-dose glucose-insulin-potassium infusion does not consistently improve final health outcomes in acute myocardial infarction patients, and may increase short-term mortality. | (−)
Acute myocardial infarction patients | 2 systematic reviews; 10 RCTs | Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and may change the estimate. | Several trials examined tight glycemic control using adjustable dose insulin-based regimens, and failed to demonstrate consistent evidence of benefit in acute myocardial infarction patients. Variation in trial design, achievement of recruitment goals, glucose level achieved, and concomitant therapy for myocardial infarction limit the strength of this conclusion. | (÷)
Acute stroke patients | 3 RCTs | Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and may change the estimate | There is very little good-quality evidence investigating tight glycemic control in patients who have suffered a cerebrovascular accident. | (÷)
Patients in medical and/or surgical intensive care units | 8 RCTs | Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate. | Single-center evidence had initially shown a mortality and morbidity benefit from IIT in subgroups of patients requiring prolonged ICU stays, but the applicability of these data to other ICUs may be limited and subsequent trials have not confirmed this benefit. Our meta-analysis found the use of intensive insulin therapy to achieve normoglycemia had a neutral effect on short-term mortality, but increased the risk of hypoglycemia more than five-fold. | (÷)
Perioperative patients | 1 systematic review; 5 RCTs | Low = Further research is likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. | Overall, there is no clear evidence showing a benefit of tight glycemic control strategies in the perioperative setting, but the trial evidence is methodologically limited. The studies varied widely in design, blood glucose levels attained, and in the inclusion of patients with diabetes, limiting the comparability of results across studies. Several studies were underpowered to evaluate health outcomes. The best quality evidence of benefit comes from the single-center SICU study discussed in the ICU section. | (÷)
General medicine ward patients | None | Very Low = Any estimate of effect is very uncertain. | There were no studies evaluating a tight glycemic control strategy to less tight glycemic control in general medical ward patients. | (0)

* (+) benefit; (−) harm; (÷) mixed findings/no effect; (0) no evidence

Table 7 Summary of Systematic Evidence Review, Key Questions 2 and 3

KQ# | Key question | Type of Evidence | Grade of Evidence | Comments
2 | What are the harms of strict glycemic control in the above subpopulations? | 1 systematic review; 15 RCTs; 12 observational studies | Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate. | There is a considerable risk of hypoglycemia in medical ICU patients treated with intensive insulin protocols designed to normalize blood glucose. This risk was lower in surgical ICU patients receiving similar therapy, and in myocardial infarction, stroke, and perioperative patients in whom the target glucose level was generally not aimed at strict euglycemia. Observational studies suggest a moderate glycemic control can be safely achieved with modest glucose targets and variations in protocol design. Some studies suggest hypoglycemia in critically ill patients may be associated with excess mortality risk. The short-term and long-term consequences of hypoglycemia have not been well-studied.
3 | What are the most effective and safest means of lowering blood glucose in the above subpopulations? | 2 systematic reviews; 2 RCTs | Low = Further research is likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate. | A number of insulin infusion protocols (IIPs) have been evaluated, but comparative effectiveness data are lacking. Protocols with moderate glucose targets appeared most feasible and were associated with the lowest hypoglycemia risk. Dynamic protocols that take into consideration the patient’s insulin sensitivity and that have guidelines built into them to help prevent hypoglycemia may be preferred. The safe and effective introduction of insulin infusion protocols in a given institution is likely an iterative and multi-disciplinary endeavor. Basal bolus subcutaneous insulin regimens may be more effective than, and at least as safe as, sliding scale regimens, though there is very limited evidence comparing methods of blood glucose control in ward patients.