# TABLE OF QUALITY RATINGS

Author, Year (ref) | Random assignment? | Allocation concealed? | Groups similar at baseline? | Eligibility criteria specified? | Blinding: outcome assessors, care provider, patient? | Intention-to- treat analysis? | Maintenance of comparable groups? | Reporting of attrition, contamination, etc? | Differential loss to followup or overall high loss to followup? | Funding source | External validity | Population-based recruitment | Comments | Quality Score
Arabi1 | yes | yes | yes | yes | NR (outcomes assessors) no (care providers) | yes | yes | yes | no | King Abdulaziz Medical City ICU reseach fund | Fair | NR | | Fair
Azevedo, 2007^2^ | yes | NR | yes | yes | NR | yes | yes | NR | NR | NR | fair | NR | insulin protocol not described, this was a subgroup analysis so numbers included were small and unequal between groups, no sig difference in blood glucose achieved | Poor
Bilotta, 2007^3^ | yes | yes | yes | yes | no | yes | NR | yes | no | departmental research funds | fair | NR | | Fair (no multivariate analysis, achieved glucose not reported)
Brunkhorst, 2008^4^ | yes | yes | Yes | Yes | NR (outcomes assessors) no (care providers) | yes | yes | yes | No | B Braun, Novo-Nordisk, Hemocue | Good | NR | | Fair
Butterworth, 2005^5^ | Yes | NR | Yes | Yes | Subjects yes; study nurse not blinded (adjusted insulin rates) | Yes | Yes | Yes | No | NR | Limited: Patients with DM were excluded; findings may not apply to that population. | No | | Fair
Ceremuzyski, 1999^6^ | yes | yes | yes | yes | NR | yes | yes | yes | no | national health and medical research council of australia | good | NR | | Fair
Cheung, 2006^7^ | yes | yes | yes | yes | NR no (care providers) | yes | yes | yes | no | national health and medical research council of australia | good | NR | | Fair (glucose differential not achieved)
Diaz, 2007^8^ | yes | yes | yes | yes | no (care providers) | yes | yes | yes | no | sanofi-aventis, organon, glaxosmithkline | good | NR | large trial | Fair
Farah, 2007^9^ | yes | NR | No: intervention group with lower day 1 glucose, and trend towards more DM2 in control group although did not reach stat sig. | Yes, excluded patients with stay < 3 days, but does not report how many | NR | NR | NR | NR | NR | NR | Poor- unable to predict who will be in ICU for more than 3 days. | NR | | Poor
Gandhi, 2007^10^ | yes | yes | Yes | Yes | Patients no; care providers no; outcome assessors yes. | No; 7-8 pts in each group were excluded because BG <100 mg/dL | Yes | Yes | No; no | Novo Nordisk, Mayo Foundation, and Mayo Clinic | Fair: included both DM and non-DM patients; only 1 study site. | No | Post-randomization exclusion: patients whose BG was <100 mg/dL during surgery were not included in the final analyses. Not blinded. | Fair
Gray, 2007^11^ | yes | yes | yes | yes | yes (outcomes assessors) no (care providers) | yes | yes | yes Moderate attrition - approx 80% were in per-protocol dataset at 90 days (I = 76.3, C = 85.3) | no - no loss to f/u for primary outcome | Stroke association and NHS | good | yes | trial was conducted well, but slow recruitment limited numbers and, since this was constructed as a "real- life" trial, incomplete data esp CBG reporting was | Poor
Grey, 2004^12^ | Yes | NR | Yes | Yes, but not well defined and number included compared to number eligible not reported | NR | NR | NR | NR | NR | NR | poor | NR | Not blinded, but # of diagnostic and microbial studies did not differ between groups. Pts were only enrolled once they | Poor
Krljanac, 2005^13^ | yes | yes | yes | yes | no | yes | yes | yes | no | NR | fair | NR | | Fair
Lazar, 2004^14^ | Yes | NR | Yes | Yes | No | Yes | Yes | Yes, none | No; no | American Diabetes Association clinical research award | Limited: comparison group had high BG target goal: <250 mg/dL | Unclear | | Fair
Li, 2006^15^ | Yes but method not described | Unclear | Yes | Yes | Not blinded | No. 7 who switched Tx were excluded from analysis | Unclear | Yes. 7 switched from SQI to CII | High: 15% loss of controls due to postrandomization exclusion | NR | Limited: target BG is same btw Tx & control | Unclear | Study not designed to address KQ | Poor
Mackenzie16 | yes | yes | No - significantly higher proportion of liver disease in control group | yes, but did not specify how anticipated LOS > 48 hours was defined | no | yes | yes | yes | no | NR | poor-fair | | | Poor
Malmberg, 1995^17^ | yes | yes | yes | yes | NR no (care providers) | yes | yes | yes | no | Swedish Heart and Lung Foundation | fair (multicenter, but nearly 50% excluded because of inability to comply with outpatient insulin regimen and concomitant therapy differs from standards today | NR | | Fair
Malmberg, 2005^18^ | yes | NR | no - control group had fewer patients with h/o prior MI | yes | NR | yes | yes | NR | NR | Swedis heart lung institute, Swedish diabetes association, King Gustav V and Queen Victoria foundation, Aventis, NovoNordisk | good | NR | | Poor
Mehta, 2005^19^ | yes | yes | yes | yes | yes (outcomes assessors) NR (care providers) | yes | yes | yes | no | No external funding - Aventis donated insulin in India | good | yes | large trial | Fair
Oksanen, 2007^20^ | yes | yes | yes | yes | NR (assessors) no (care providers) | yes | yes | yes | no | Laedral foundation and Instrumentarium foundation | fair | NR | | Fair
Pache, 2004^21^ | yes | NR | yes | yes | NR | yes | NR | NR | NR | NR | fair | NR | Not enough information reported regarding initial and follow-up glycemic measure | Poor
Preiser22 | yes | yes | yes | yes | yes (outcome assessors) no (care providers) | yes | yes | yes | no | NR | good | NR | | Fair
Rasoul, 2007^23^ | yes | NR | yes | yes | no | yes | yes | yes | no | Netherlands Heart foundation and Guidant | fair | NR | Lack of reporting of glucose achieved and hypoglycemic events limits interpretation of results | Poor
Smith, 2002^24^ | yes | NR | yes | yes | NR | yes | yes | yes | no | NR | Limited: small sample size | NR | small pilot study - reasonable study design, but underpowered for reported heatlh outcomes | Poor
Turel, 2005^25^ | reported as randomized, but appears as though assignment to groups was consecutive | no | yes | not clearly | NR | NR | yes | NR | NR | NR | limited - not enough information reported on exclusion criteria, # eligible vs # enrolled | NR | | Poor
van den Berghe, 2001^26^ | yes | yes | yes | yes | yes (outcome assessors) no (care providers) | yes | yes | yes | No | Univ of Leuven, Belgian Fund for scientific research, Novo-nordisk | poor-fair: single center, aggressive nutrition practices used, arterial blood sampling used | NR | | Fair
Van den Berghe, 2006^27^ | yes | Yes | yes | Yes | yes - only for clinical cause of ICU death no (care providers) | yes | yes | yes | no | Univ of Leuven, Belgian Fund for scientific research, | Fair | NR | | Fair
van der Horst, 2003^28^ | yes | NR | yes | yes | NR | yes | yes | NR | no | NR | good - acute MI treatment reasonably reflects current practice and current MI mortality rates | no | methodology not fully reported | Fair

## References in Quality Ratings Table

1 Arabi YM, Dabbagh OC, Tamim HM, et al. Intensive versus conventional Insulin therapy: a randomized controlled trial in medical and surgical critically ill patients. Accepted for publication.
2 Azevedo JRAd, Lima ERM, Cossetti RJD, Azevedo RPd. Intensive insulin therapy versus conventional glycemic control in patients with acute neurological injury: a prospective controlled trial. Arquivos de Neuro-Psiquiatria. Sep. 2007;65(3B):733-738. [pmid: 17952272].
3 Bilotta F, Spinelli A, Giovannini F, Doronzio A, Delfini R, Rosa G. The effect of intensive insulin therapy on infection rate, vasospasm, neurologic outcome, and mortality in neurointensive care unit after intracranial aneurysm clipping in patients with acute subarachnoid hemorrhage: a randomized prospective pilot trial. Journal of Neurosurgical Anesthesiology. Jul. 2007;19(3):156-160. [pmid: 17592345].
4 Brunkhorst FM, Engel C, Bloos F, et al. Intensive Insulin Therapy and Pentastarch Resuscitation in Severe Sepsis. New England Journal of Medicine. January 10, 2008. 2008;358(2):125-139. [pmid: 18184958].
5 Butterworth J, Wagenknecht LE, Legault C, et al. Attempted control of hyperglycemia during cardiopulmonary bypass fails to improve neurologic or neurobehavioral outcomes in patients without diabetes mellitus undergoing coronary artery bypass grafting. Journal of Thoracic & Cardiovascular Surgery. Nov. 2005;130(5):1319. [pmid: 16256784].
6 Ceremuzyski L, Budaj A, Czepiel A, et al. Low-dose glucose-insulin-potassium is ineffective in acute myocardial infarction: results of a randomized multicenter Pol-GIK trial. Cardiovascular Drugs & Therapy. May. 1999;13(3):191-200. [pmid: 10439881].
7 Cheung NW, Wong VW, McLean M. The Hyperglycemia: Intensive Insulin Infusion in Infarction (HI-5) study: a randomized controlled trial of insulin infusion therapy for myocardial infarction. Diabetes Care. Apr. 2006;29(4):765-770. [pmid: 16567812].
8 Diaz R, Goyal A, Mehta SR, et al. Glucose-insulin-potassium therapy in patients with ST-segment elevation myocardial infarction. JAMA. Nov 28. 2007;298(20):2399-2405. [pmid: 18042917].
9 Farah R, Samokhvalov A, Zviebel F, Makhoul N. Insulin therapy of hyperglycemia in intensive care. Israel Medical Association Journal: Imaj. Mar. 2007;9(3):140-142.
10 Gandhi GY, Nuttall GA, Abel MD, et al. Intensive intraoperative insulin therapy versus conventional glucose management during cardiac surgery: a randomized trial. Annals of Internal Medicine. Feb 20. 2007;146(4):233-243. [pmid: 17310047].
11 Gray CS, Hildreth AJ, Sandercock PA, et al. Glucose-potassium-insulin infusions in the management of post-stroke hyperglycaemia: the UK Glucose Insulin in Stroke Trial (GIST-UK). Lancet Neurology. May. 2007;6(5):397-406. [pmid: 17434094].
12 Grey NJ, Perdrizet GA. Reduction of nosocomial infections in the surgical intensive-care unit by strict glycemic control. Endocrine Practice. Mar-Apr. 2004;10(Suppl 2):46-52. [pmid: 15251640].
13 Krljanac G, Vasiljevi Z, Radovanovi M, et al. Effects of glucose-insulin-potassium infusion on ST-elevation myocardial infarction in patients treated with thrombolytic therapy. American Journal of Cardiology. Oct 15. 2005;96(8):1053-1058. [pmid: 16214437].
14 Lazar HL, Chipkin SR, Fitzgerald CA, Bao Y, Cabral H, Apstein CS. Tight glycemic control in diabetic coronary artery bypass graft patients improves perioperative outcomes and decreases recurrent ischemic events. Circulation. Mar 30. 2004;109(12):1497-1502. [pmid: 15006999].
15 Li J-Y, Sun S, Wu S-J. Continuous insulin infusion improves postoperative glucose control in patients with diabetes mellitus undergoing coronary artery bypass surgery. Texas Heart Institute Journal. 2006;33(4):445-451. [pmid: 17215967].
16 Mackenzie IM, Blunt M, Ingle S, Palmer CR. GLYcaemic Control and Outcome in GENeral Intensive Care: The East Anglian GLYCOGENIC study. Unpublished report.
17 Malmberg K, Ryden L, Efendic S, et al. Randomized trial of insulin-glucose infusion followed by subcutaneous insulin treatment in diabetic patients with acute myocardial infarction (DIGAMI study): effects on mortality at 1 year. Journal of the American College of Cardiology. Jul. 1995;26(1):57-65. [pmid: 7797776].
18 Malmberg K, Ryden L, Wedel H, et al. Intense metabolic control by means of insulin in patients with diabetes mellitus and acute myocardial infarction (DIGAMI 2): effects on mortality and morbidity. European Heart Journal. Apr. 2005;26(7):650-661. [pmid: 15728645].
19 Mehta SR, Yusuf S, Diaz R, et al. Effect of glucose-insulin-potassium infusion on mortality in patients with acute ST-segment elevation myocardial infarction: the CREATE-ECLA randomized controlled trial. JAMA. Jan 26. 2005;293(4):437-446. [pmid: 15671428].
20 Oksanen T, Skrifvars MB, Varpula T, et al. Strict versus moderate glucose control after resuscitation from ventricular fibrillation. Intensive Care Medicine. Dec. 2007;33(12):2093-2100. [pmid: 17928994].
21 Pache J, Kastrati A, Mehilli J, et al. A randomized evaluation of the effects of glucose-insulin-potassium infusion on myocardial salvage in patients with acute myocardial infarction treated with reperfusion therapy. American Heart Journal. Jul. 2004;148(1):e3. [pmid: 15215812].
22 Preiser JC. NIH. Glucontrol Study: Comparing the Effects of Two Glucose Control Regimens by Insulin in Intensive Care Unit Patients. http://www.clinicaltrials.gov/ct/gui/show/NCT00107601. Submitted for publication.
23 Rasoul S, Ottervanger JP, Timmer JR, et al. One year outcomes after glucose-insulin-potassium in ST elevation myocardial infarction. The Glucose-insulin-potassium study II. International Journal of Cardiology. Oct 31. 2007;122(1):52-55. [pmid: 17223212].
24 Smith A, Grattan A, Harper M, Royston D, Riedel BJCJ. Coronary revascularization: a procedure in transition from on-pump to off-pump? The role of glucose-insulin-potassium revisited in a randomized, placebo-controlled study. Journal of Cardiothoracic & Vascular Anesthesia. Aug. 2002;16(4):413-420. [pmid: 12154417].
25 Turel B, Gemici K, Baran I, et al. Effects of glucose-insulin-potassium solution added to reperfusion treatment in acute myocardial infarction. Anadolu Kardiyoloji Dergisi. Jun. 2005;5(2):90-94. [pmid: 15939681].
26 van den Berghe G, Wouters P, Weekers F, et al. Intensive insulin therapy in the critically ill patients. New England Journal of Medicine. Nov 8. 2001;345(19):1359-1367. [pmid: 11794168].
27 Van den Berghe G, Wilmer A, Hermans G, et al. Intensive insulin therapy in the medical ICU. New England Journal of Medicine. Feb 2. 2006;354(5):449-461. [pmid: 16452557].
28 van der Horst ICC, Zijlstra F, van't Hof AWJ, et al. Glucose-insulin-potassium infusion inpatients treated with primary angioplasty for acute myocardial infarction: the glucose-insulin-potassium study: a randomized trial. Journal of the American College of Cardiology. Sep 3. 2003;42(5):784-791. [pmid: 12957421].