# INCLUSION/EXCLUSION CRITERIA

Code | Include/Exclude | Reason
I | Include | Clinical trial, cohort study, systematic review/meta-analysis of studies that; A. Were conducted in any of the following populations:; 1. Acute myocardial infarction patients; 2. Other patients in the medical intensive care unit; 3. Post coronary artery bypass graft patients; 4. Other patients in the surgical intensive care unit; 5. Acute stroke patients; 6. General medicine ward patients; 7. General surgical ward patients; B. Include any of the following interventions:; 1. Continuous IV insulin infusion; 2. GIK, GI; 3. SQ insulin: sliding scale v. basal bolus; C. Examine any of the following endpoints:; 1. Final outcomes: mortality; cardiovascular events; CHF; disability (neuro-disability score); wound infection; sepsis; renal failure requiring HD; 2. Intermediate outcomes: glucose level; length of stay; renal failure not requiring HD; 3. Adverse effects – rates of hypoglycemia (any study design); D. To address KQ3, applied rigorous methodology (controlled clinical trials including RCTs)
I | Include | Unpublished research meeting I1 criteria
I | Include | Other (specify)
X1 | Exclude | Study outcome does not meet I1 criteria – effects on nursing staff of IV-insulin infusion protocols, e.g.
X2 | Exclude | Study population does not meet criteria
X3 | Exclude | Type of intervention not within scope of review
X4 | Exclude | Other (specify)
X5 | Exclude | Non-English language, no abstract
X6 | Exclude | Non-human, animal
X7 | Exclude | Study design or publication type not applicable; no data
X8 | Exclude | Non-systematic review or background article; poor-quality systematic review
X9 | Exclude | Publication year outside of review time frame
X10 | Exclude | Duplicate publication, subgroup analysis, or extension of already included parent study – these papers will be re-examined and abstracted along with parent study