# SEARCH STRATEGY

Database: Ovid MEDLINE(R) <1950 to November Week 2 2007>
Search Strategy:
1 | exp insulin/(130835)
2 | exp hypoglycemic agents/(151706)
3 | exp Blood Glucose/(98489)
4 | (insulin or hypoglycemic agent$ or hypoglycaemic agent$ or glycemic control or glycaemic control).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (243159)
5 | 1 or 2 or 3 or 4 (292506)
6 | Critical Illness/(8301)
7 | critical care/or intensive care/(28092)
8 | exp Perioperative Care/(60582)
9 | exp Postoperative Period/(28181)
10 | ((critical$ adj6 ill$) or critical care or icu or intensive care or burn unit$ or coronary care).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (103498)
11 | intensive care units/or burn units/or coronary care units/or recovery room/(27247)
12 | postoperative complications/or prosthesis-related infections/or surgical wound dehiscence/or surgical wound infection/(252519)
13 | (postoperative$ or post operative$).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (457854)
14 | 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (582795)
15 | 5 and 14 (5822)
16 | randomized controlled trial.pt. (246761)
17 | controlled clinical trial.pt. (77022)
18 | randomized controlled trials.sh. (52472)
19 | random allocation.sh. (59778)
20 | double blind method.sh. (94781)
21 | single blind method.sh. (11591)
22 | 16 or 17 or 18 or 19 or 20 or 21 (418296)
23 | (animals not human).sh. (4261058)
24 | 22 not 23 (382274)
25 | clinical trial.pt. (444490)
26 | exp clinical trials/(199910)
27 | (clin$ adj25 trial$).ti,ab. (139332)
28 | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab. (94254)
29 | placebos.sh. (26956)
30 | placebo$.ti,ab. (106977)
31 | random$.ti,ab. (394441)
32 | research design.sh. (50582)
33 | 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 (887876)
34 | 33 not 23 (778635)
35 | 34 or 24 (798240)
36 | 15 and 35 (979)
37 | exp Myocardial Infarction/(115916)
38 | exp Hospitalization/(107713)
39 | exp Inpatients/(6673)
40 | exp Cerebrovascular Accident/(44100)
41 | cerebrovascular disorders/or brain ischemia/or exp “intracranial embolism and thrombosis”/or exp intracranial hemorrhages/(112871)
42 | exp myocardial revascularization/or exp coronary artery bypass/(56866)
43 | 37 or 40 or 41 or 42 (300510)
44 | 5 and 43 (4061)
45 | 35 and 44 (657)
46 | 45 not 36 (544)
47 | 38 or 39 (113294)
48 | 5 and 47 (1078)
49 | 35 and 48 (202)
50 | 49 not (36 or 46) (114)
51 | exp Hypoglycemia/ci, ep, et [Chemically Induced, Epidemiology, Etiology] (8651)
52 | 1 or 2 or 4 (250082)
53 | 51 and 52 (5520)
54 | 14 and 53 (180)
55 | 43 and 53 (41)
56 | 47 and 53 (65)
57 | 54 or 55 or 56 (276)
58 | 57 not (36 or 46 or 49) (254)
59 | exp Hypoglycemia/(17277)
60 | 52 and 59 (9545)
61 | 14 and 60 (285)
62 | 43 and 60 (86)
63 | 47 and 60 (97)
64 | 61 or 62 or 63 (445)
65 | 64 not 57 (169)
66 | 65 not (36 or 46 or 49) (152)
67 | limit 36 to english language (865)
68 | limit 46 to english language (476)
69 | limit 50 to english language (104)
70 | limit 58 to english language (215)
71 | limit 66 to english language (113)
72 | from 67 keep 1-865 (865)
73 | from 68 keep 1-476 (476)
74 | from 69 keep 1-104 (104)
75 | from 70 keep 1-215 (215)
76 | from 71 keep 1-113 (113)

An additional search for adverse effects used the strategy above through line 71, followed by:

72 | (ae or po or to).fs. (1254721)
73 | exp Drug Toxicity/(15829)
74 | medical errors/or medication errors/(13158)
75 | exp Drug Interactions/(116890)
76 | 72 or 73 or 74 or 75 (1359022)
77 | 1 or 3 (186918)
78 | 6 or 7 or 8 or 9 or 11 or 12 (379861)
79 | 77 and 78 (2545)
80 | 76 and 79 (364)
81 | limit 80 to english language (296)
82 | limit 81 to humans (276)
83 | 15 and 76 (871)
84 | limit 83 to english language (725)
85 | limit 84 to humans (668)
86 | 85 not 82 (392)
87 | from 82 keep 1-276 (276)
88 | from 86 keep 1-392 (392)