# SUMMARY AND DISCUSSION

Our review of the evidence suggests that there is no easily generalizable path into homelessness. Both Veteran and non-Veteran homeless individuals are more likely than those in the general population to have been exposed to one or more risk factors such as childhood instability or trauma, mental illness, alcohol or substance abuse, chronic illness, low social support in adulthood, and low or unstable income. However, the precise strength of the association of each of these factors with the outcome of homelessness remains poorly measured, both for the Veteran homeless population as a whole and for sub-populations of interest such as women Veterans. This is due in part to the lack of studies designed to examine the directionality of relationships of these variables to the outcome of homelessness, but also in part to the inherently complex process of becoming homeless, which occurs as the result of multiple influences (both structural and individual), each with various potential moments of intervention.

While homeless Veterans are exposed to much the same broadly defined risk factors as other homeless individuals, the qualitative nature of those exposures will in some cases be different because of Veterans’ experiences during military service or during the post-deployment period. The conceptual model developed for this report is a first step in identifying areas where we need to gather stronger evidence in order to understand how the unique experiences of Veterans, such as combat exposure or readjustment difficulty, might be contributing to their risk of experiencing other more generally shared risk factors for homelessness such as low or unstable income.

Veteran homelessness is unique in that some factors generally believed to be protective, such as being better educated or having better social support, do not appear to have quite the same protective efficacy in the Veteran population. While we have speculated in this report that their experiences as Veterans might somehow actively work against the protective value associated with these factors in other populations, this is an area which has not been adequately researched and where longitudinal research employing mixed methods would be of great value in substantiating or refuting such a hypothesis.

Veterans become separated from their normative communities in different ways: physically, through enlistment in the military or incarceration in jail or prison, and socially and culturally through mental illness, substance abuse, and disability. Each presents its own challenges for re-entry into and re-integration with support networks in former communities. The Veteran “advantage” in better social support is hypothesized on the basis of repeated measures of higher rates of ever-marriage, but as other authors have pointed out, this may not be the most meaningful measure of social support in this context. It is possible that the additional financial and emotional responsibilities of supporting a spouse and dependents may, under certain circumstances, actually enhance the risk of homelessness. As with education, however, higher levels of social support among homeless Veterans as compared to homeless non-Veterans does not appear to offer protection against homelessness.

While recent trends in the number of Veteran homeless are encouraging, studies suggesting that lowered recruitment standards may be related to the increase in homelessness among Veterans of the early all volunteer force should, if true, make us alert to a potential increase in homelessness among Operation Iraqi Freedom (OIF)/Operation Enduring Freedom (OEF) Veterans who were similarly recruited with lowered standards.109, 110

As mentioned in the introduction, ending homelessness entails the two distinct tasks of relieving homelessness among those who currently lack housing, and preventing the occurrence of homelessness among those at risk. The existing evidence illustrates in many ways the methodological difficulties inherent in identifying risk factors, such as mental illness, in a population where the condition of interest (homelessness) is likely to produce the risk factor. Causal links between many individual level factors and homelessness have not been well-established in the literature, and there may be a bi-directional relationship between homelessness and risk factors such as mental illness, substance abuse and incarceration. Moreover, given that homelessness may not occur for many years after deployment, targeting military level risk factors may be difficult, especially during the post-deployment period. It may be important to repeatedly engage and evaluate Veterans both qualitatively and quantitatively for years after service. Large-scale, long-term longitudinal studies, such as the Department of Defense Millenium Cohort Study, provide important opportunities for this type of research.31 Furthermore, an assessment of a given Veteran’s risk for homelessness will be incomplete if only individual level risk factors are evaluated. The structural level risk factors of the environment (affordable housing, employment opportunities) into which a Veteran has re-integrated need to be assessed as these are likely to contribute to the homelessness risk milieu.

## RECOMMENDATIONS FOR FUTURE RESEARCH

This report identifies a number of gaps in the literature and makes key suggestions to define the agenda for future research on Veteran homelessness:

- Longitudinal studies with Operation Enduring Freedom (OEF)/Operation Iraqi Freedom (OIF) Veterans are needed to capture data on exposures occurring before homelessness occurs. Given the VA’s current policy of pro-active enrollment and engagement of this cohort, opportunities exist to conduct longitudinal studies that collect information on all of the risk factors identified in this report. This research should control for structural risk factors such as housing market costs and available assistance programs.
- Longitudinal studies with all new cohorts of enlisting military service members could better determine the pre-existing presence of risk factors, such as low social support, alcohol or substance abuse problems, before military service. Policies should be developed to facilitate the use of data from enlistment screenings in research.
- Qualitative studies employing longitudinal, ethnographic methods to investigate the distinct experiences of homeless Veterans will help researchers to understand what is unique about Veteran exposure to risk factors common to the general homeless population. This remains poorly understood at present but may have important implications for designing homelessness prevention programs that will be effective for Veterans.
- Current research suggests that risk for violent criminal behavior varies by service branch. Research to confirm these differences and how to identify individuals at risk for continued post-military violent criminal behavior may help target interventions to those most at risk for post-military incarceration.
- Research on the post-deployment period is needed, with a particular focus on risk factors for loss of income and social support during this transition period, as well as rates of short-term homelessness experienced during this period. These data could be collected as part of longitudinal studies looking for relationships between short-term and more chronic homelessness in the longer term, which has been the focus of past research.
- Further research on military sexual trauma (MST), its relationship to homelessness, and appropriate MST prevention and treatment programs, is recommended.
- Research on Veterans Courts and other specialty courts should be continued in order to improve their performance and find effective alternatives to incarceration for Veterans.
- Systems perspective research on collaborations among Departments of Corrections, the VA, the Department of Housing and Urban Development (HUD), and local community health agencies could inform efforts to reduce the likelihood of homelessness upon re-entry from incarceration, including developing a better understanding of how to identify those most at risk for homelessness post-release.
- Most of the measures used to assess risk factors and personal characteristics of the homeless, including measures of substance abuse, mental health, and measures of social support, have been developed and normed on populations very different from the homeless. The applicability of these measures to homeless populations is unknown. Research should be undertaken to assess the applicability of these measures and to modify or develop new measures where warranted. Similarly, better defined research on the aspects of social support most relevant to improving Veterans’ post-deployment adjustment would contribute both to addressing Veteran homelessness and the literature’s broader understanding of the function of social support.
- Long-term studies repeatedly collecting both quantitative and qualitative data, though always relatively difficult and costly to conduct, would greatly improve our understanding of Veterans’ difficulties in re-engagement and re-integration over long periods of time after deployment, not just in the initial post-deployment year which is more frequently studied.
- Studies that include both individual and structural risk factors should be conducted to assess both their independent and contingent effects.
- Research is needed to investigate the relationship between the unique Veteran experience of “family readjustment difficulties” in the post-deployment period and other, more generalized concepts such as social support, as well as the relationship between family readjustment difficulties and clinical diagnoses of mental illness.
- To our knowledge, the direct relationship between injury/disability and increased risk of homelessness has not been well studied in the Veteran population. There is a need for research designed to examine injury as a risk factor for homelessness, both directly and indirectly, and taking into account the complex effects of serious injury on both income and quality of life/well-being.